# Acknowledgments

We would like to thank Chris Stave, Liaison and Instructional Services Coordinator at Stanford University Lane Medical Library, for his invaluable support in developing and conducting the literature search. We also appreciate the constructive feedback on the draft report from the following voluntary peer reviewers: John Bott, Karen Davis, Paul Ginsburg, Judith Hibbard, David Hopkins, Daniel Kessler, and Stephen Parente. The final report does not fully address all of their input because of the limited scope of this report as an exploratory analysis as opposed to a complete evidence report.

The authors of this report have no financial conflicts or interests with products, companies or persons mentioned in this study.