# Concluding Observations and Policy Questions

A full understanding of the effects of different consumer-oriented strategies will require extensive additional analysis. Our conceptual model points out the need to study these types of activities in a range of settings in order to fully determine their likely effects. Existing studies are sparse and do not yet provide the needed breadth. This is quite understandable, given the short time that CDHPs and other strategies have been around. Literature on these activities will undoubtedly develop further in coming years.

This report was not intended to serve as a policy setting document. Its scope is to identify conceptual issues related to the interpretation of literature on consumer-oriented strategies, and to provide information from initial inquiries into the state of the literature. Developing a framework for advancing research and policy development in the area of consumer-oriented strategies would, in many ways, be a different undertaking. At the same time, the findings in this report do suggest some important areas for potential future inquiry. Perhaps the overriding policy question in this area is the extent to which new policies should be developed that would encourage or discourage further development of consumer-oriented strategies. More refined questions might focus on which specific strategies should be emphasized or deemphasized, and the extent to which policies should be specific to particular patients or settings.

Existing work is insufficient to answer these questions. Developing well-informed policy will require additional analysis of the cost implications of different strategies, including effects on premiums, out-of-pocket spending by consumers, and spending by health plans. In the case of CDHPs, longer term effects of the PHAs, such as the implicit savings for future medical needs when funds are rolled over, on behavior and future health care consumption would also have to be examined, as would the impacts of increasing the amount of risk borne by consumers. Sound policymaking would also require an understanding of the implications on health care consumption and quality of care, including issues such as the extent to which increased financial responsibility deters consumers from seeking preventive care and other appropriate care.

While some work on these topics has been undertaken, available literature addresses only some of the important underlying questions. More importantly, existing literature addresses these questions in specific circumstances. While, almost by definition, studies will speak most clearly to the specific context within which they are conducted, we believe that the impacts of consumer-oriented strategies could vary substantially from one setting to the next. Ultimately, a range of studies that investigate the impacts of consumer-oriented strategies in different contexts, with different kinds of consumers facing different choice sets, will be required to fill in the picture to the point where the landscape will be sufficiently clearly visible for truly informed policymaking. At this point further primary studies appear to be a priority, and further systematic synthesis less valuable.