# Observations on the Literature on Comparative Quality Reporting About Providers

In general, the literature on quality of care and related issues is very large, encompassing a wide range of topics from identification of appropriate things to measure, to empirical strategies for measurement, to the design of statistical models and risk adjustment methods, to the methods for reporting results, to the ultimate impact that collecting information has on the behavior of health care providers and patients. Quality improvement efforts have been focused on different providers including doctors and groups of doctors, hospitals, long term care settings, and other entities. Some efforts focus on specific health care conditions while some are more general. Efforts to disseminate quality data have targeted individual consumers, groups of consumers, employers, and others. The collective inquiry by numerous researchers and others into issues related to quality has produced a very large literature. Indeed, an Ovid MEDLINE® search on the keyword “quality” in the subject headings Quality Indicators, Health Care, Quality Control, Total Quality Management, Quality Assurance, Health Care, and “Quality of Health Care” yields more than 200,000 citations between 1966 and the present.

Sifting through this literature would be a daunting task without serious efforts to focus the inquiry. In the context of CDHPs, it seems likely that the most valuable searches would target literature on the effects of the dissemination of information about health care providers. However, there are no MESH subject headings related specifically to this area yet. Thus, culling through the quality literature to comprehensively identify the set of articles related to this specific literature seems likely to be a significant undertaking. A report on public reporting of quality data was produced about three years ago by Patrick Romano and Julie Rainwater for AHRQ, and summarized the state of current efforts at the time and evaluative evidence about public reporting of health care performance data. ^64^ The report aimed to provide salient background for guidance to the AHRQ Quality Indicators program on what indicators might be more or less suitable for public reporting.