# Observations on the Size and Content of Literature on Tiering

In addition to reviewing of the CDHP literature, we conducted a preliminary investigation into the state of the literature on tiered networks. We searched OVID MEDLINE® using the following search string:

(exp Health Maintenance Organizations/ or exp Health Benefit Plans, Employee/ or exp Insurance, Health/ or exp State Medicine) and (“tier$”).mp

This search yielded 218 articles. We reviewed the titles and abstracts of these 218 articles, and found that almost all of them were something other than studies of the effects of tiered health care provider networks on health care use, costs, or outcomes. Most of the excluded articles fell into one of three categories: studies of tiered pharmacy benefit designs, studies of health care systems in other countries in which there are different tiers of health care coverage, and studies of the U.S. health care system in which the term “tier” is used to refer to different levels of coverage or access to health care providers (e.g., the uninsured getting “second tier” access). Only about 10 studies appeared to be suitable for further investigation. Based on the titles and abstracts, we assume that a reasonably large percentage of these would ultimately be found not to report the results of scientific studies that investigated the impacts of tiered networks on health care use, costs, or outcomes.

In this preliminary investigation, we observed no indication that this literature would provide a basis for comparisons between tiered networks and other consumer-oriented strategies, or information about the ways that tiered networks interact with other consumer-oriented strategies. The Rand Corporation report on consumer-oriented strategies also reported finding limited evidence about the effects of tiered network plans.