# Review of the Literature on CDHPs

In this section we report results of a review of literature on consumer directed health plans (CDHPs). As defined above, these plans typically pair a high-deductible plan with a tax-advantaged spending account and, in many cases, provide consumers with information about the cost and quality of care to make purchasing decisions. The objective of the literature search was to conduct a comprehensive review of the published scientific literature that provides evidence specific to CDHPs.

## Key Questions

We broadly defined the literature of interest as studies of either the prevalence or effects of CDHPs, and we identified the following key questions for which we sought evidence from the literature:

CDHPs Prevalence

- What are prevalence rates and expected trends for CDHPs?

Consumer-driven Strategies and Quality-improvement

- What is the evidence on the effect of CDHPs on quality improvement or lack of improvement?

Consumer-driven Strategies and Access to Care

- What is the evidence that consumer directed health plans affect utilization of health care services, including doctors visits, ER visits, medications, and diagnostic tests? Is there evidence to determine whether effects on utilization are related to necessary vs. unnecessary services? What is the evidence that consumer-directed health plans discourage access to appropriate care?
- Is there evidence that effects of CDHPs on utilization vary depending on the underlying health status, income or education of individuals?

Consumer-driven Strategies and Cost-containment

- What is the evidence that consumer-directed health plans reduce health care expenditures?

Based on our conceptual model, which indicates that the selection of individuals into CDHPs may affect analyses of their effects, we also included the following research question:

Enrollment in Consumer Driven Health Plans

- Are certain types of individuals more likely than others to enroll in these plans?

## Literature Review Methods

### Inclusion and Exclusion Criteria

Our literature review included studies of the prevalence or effects of CDHPs. For a prevalence study, the inclusion criteria were that it had to include original survey data that was representative of a defined geographic area. A study of the effects of CDHPs had to be based on the implementation of an actual CDHP with clearly articulated research methods. In other words, we excluded theoretical discussions of the likely effects of CDHPs as well as studies that simulated the effects of CDHPs based on estimates derived from studies not specific to CDHPs. Estimates of the effects of CDHPs, such as those from firms implementing the plans or consultants, were not included if they did not provide adequate information to identify the methods used in the study. We did not restrict our analysis to randomized controlled trials. Although these types of studies provide the highest quality evidence, we felt it was unlikely that any studies meeting this criterion existed. In addition, we also felt that studies that were not randomized could provide valuable evidence. For the purposes of the literature review, we defined a CHDP as a high deductible health plan combined with a spending account.

### Search Strategy

The objective of the search strategy was to identify all published articles estimating the prevalence and effects of CDHPs satisfying the search criteria outlined above. We divided the search into 4 sections intended to identify literature using different key concepts. The first search was for studies that explicitly examined consumer driven health plans using a comprehensive list of key words and acronyms. The second search was based on the existence of a reimbursement, saving, or spending account. The third searched for the phrase “high deductible”, and the final search was based on acronyms for the spending accounts. Because the acronyms are used for a variety a non-related terms (for example M.S.A. is used for both medical savings account and metropolitan statistical area), we combined these acronyms with search terms intended to limit the results to applicable topic areas.

We searched both Medline (using OVID) and Econlit to incorporate both the medical and economics literatures. Using OVID, we searched Ovid MEDLINE (R) In-Process and Other Non-Indexed Citations (1966-present). For both databases, the searches were current as of January 31, 2006.

### Database Searches

We searched Econlit and MEDLINE® using the search terms identified in Tables 1 and 2.

Table 1 Econlit searches and number of articles identified

Search Terms | Citations Retrieved
( (“consumer directed” OR “consumer-directed” OR “consumer driven” OR “consumer-driven” OR “consumer health plan*” OR “consumer healthcare plan*” OR “CHDP” OR “CDHC” ) ) | 25
( ( (“reimbursement account*” OR “saving account*” OR “savings account*” OR “spending account*”) and (health* OR medic*) ) ) | 62
( ( “high deductible*” OR “high-deductible*” ) ) | 6
( ( health OR medic* ) And ( hsa* OR msa* OR hcra* OR hra* ) ) | 46
Number of Unique References | 125

Table 2 MEDLINE® searches and number of articles identified

Search Terms | Citations Retrieved
(“consumer directed” or “consumer-directed” or cdhp or cdhc or “consumer driven” or “consumer-driven” or “consumer health plan$” or “consumer healthcare plan$”).mp. | 352
exp “medical savings accounts”/ or “reimbursement account$”.mp. or “saving account$”.mp. or “savings account$”.mp. or “spending account$”.mp. | 367
(“high deductible$” or “high-deductible$”).mp. | 19
(exp “Health Care Economics and Organizations”/ or exp “Consumer participation”/) and (hsas or hsa or msas or msa or hcras or hcra or hra or hras).mp. | 473
Number of Unique References | 1096

## Results for the Literature Search

### Articles Included

Our database searches resulted in 125 citations from Econlit and 1,096 from MEDLINE®. We included for further consideration all materials that were identified in MEDLINE or Econlit. This captured some studies that were indexed, but which did not appear in peer-reviewed journals. We eliminated 87/979 based on either title or abstract review. We evaluated the remaining articles based on a full text review. In the full text review, we eliminated an additional 32/107 articles. After these exclusions, we were left with 6 citations from Econlit and 10 from MEDLINE. The number of unique articles was 10.

During our full-text review, we identified and attempted to retrieve a number of additional articles or sources of information. In many cases, they were studies produced by private firms that are not publicly available. For example, Lee and Zappert ^31^ report data from a study produced in 2005 by Harris Interactive, yet we were unable to obtain a copy of the report from the organization. We also searched the websites of select research organizations to identify additional reports not published in the academic literature. These included the California Healthcare Foundation, The Commonwealth Fund, The International Health Economics Association, The American Public Health Association, The National Bureau of Economic Research, The Economic Research Initiative on the Uninsured, The Employee Benefits Research Institute, The Robert Wood Johnson Foundation, and The Kaiser Family Foundation. While we identified work in process through these sources, we did not include them in our review since they were not finalized. The six additional citations identified in Table 3 represent studies we identified through these types of sources. Of these 6 citations, we added 1 which met our review criteria.

Table 3 Identification of reviewed studies

| Econlit | Medline
Total citations retrieved | 125 | 1096
Excluded based on title and/or abstract review | 87 | 979
Excluded based on full text review | 32 | 107
Total articles eligible for review | 6 | 10
Number of unique articles reviewed from literature search | 10
Additional articles identified during review process and retrieved | 6
Additional articles reviewed | 1
Total number of articles included in the literature review | 11

### Articles Excluded

Ultimately we reviewed a relatively small subset of the articles we identified. In this section, we discuss the major types of reasons articles were excluded:

- Citations were not in the relevant subject area
  Analysts use a variety of different terms to describe the types of health insurance plans that met the study criteria. For example, a plan of this type can be referred to as a “consumer-directed health plan,” a “consumer-driven health plan,” or a “high-deductible health plan,” and each of these terms may have a corresponding acronym (e.g., - CDHP and CDHC). The spending accounts associated with these plans are also identified by a variety of terms and associated acronyms including health savings accounts (HSAs), health spending accounts (HSAs), health reimbursement arrangements or accounts (HRAs), and medical savings accounts (MSAs). Yet, the terms used to describe both the plans and the savings accounts are sufficiently general that they identify research on unrelated topics. As a result, designing a search strategy that incorporated the full range of commonly used terms to describe these plans resulted in a relatively large number of false positives. Although some of these articles were in distinctly different literatures, ^32^ a significant number represented studies in the area of health services research. For example, our acronym list identified references to Health Systems Agencies (HSAs) established during the 1970s, ^33^ The New York State Health Care Reform Act (HCRA), ^34^ metropolitan statistical areas (MSAs), ^35^ and master settlement agreement (MSA). ^36^ By including the term “spending account” in our search, we retrieved articles on flexible spending accounts. ^37^ This was also an issue with respect to the terms used to describe the health insurance plans. For example, our search strategy identified studies of “consumer-directed advertising” ^38^ and “consumer-directed services.” ^39^ We were able to exclude many of these types of studies based on the abstract review.
- Studies of the implementation of similar types of plans in other countries
  A relatively small literature exists describing the experience of the few countries, most notably Singapore, that have adopted a version of medical savings accounts in their health care system. ^40^ We ultimately excluded these studies because the structure of the plans and the environment in which they were implemented differs significantly from that of the U.S., limiting the applicability of the experience with these plans in other countries for U.S. decision makers. In addition, Dixon, ^41^ who summarizes this literature, concludes that much of the international literature is theoretical and the empirical studies that exist do not provide strong evidence of the effects of MSAs.
- Studies of hypothetical choices made by either consumers or employers.
  We excluded studies based on data from surveys of individuals regarding how they were likely to respond in particular situations due to the uncertainty regarding how these findings translate into actual decisions. This exclusion applied to studies of both potential plan enrollees ^42^ as well as employers. ^43^
- Simulations of the likely effects of adopting these types of plan.
  Researchers have also conducted simulations of the likely effects of adopting these types of plans, and much of the literature examining the effects of the implementation of MSAs is based on simulations. ^44^ Simulations are generally based on behavioral parameters developed from existing studies, making assumptions and conducting sensitivity analyses when necessary, and analyze the adoption of these plans under a particular set of circumstances. In the case of high deductible health insurance accompanied by a spending account, estimating the effects requires estimating both the effect of enrolling in the plan on utilization and outcomes as well as the types of individuals that are likely to enroll in a plan under particular circumstances. Estimating the selection effects requires making assumptions regarding the behavior of employers, insurers and consumers, and the selection effect will ultimately influence estimates of the utilization effects. While these studies have demonstrated that the likely effects of these plans in the form of reduced utilization and higher cost sharing ultimately depends on what types of individuals enroll, they also point to considerable uncertainty in both the types of individuals who would enroll and the ultimate impact on the stability of the insurance market. ^44^ – ^47^ In a similar vein, relatively recent studies simulating the impact of legislation enabling the implementation of health savings accounts have also reached somewhat differing conclusions on their likely effects on the number of uninsured. ^48,^ ^49^ Studies that incorporate simulation approaches have also been reviewed in the recent report from the Rand Corporation. ^4^ In summary, we think that the simulation results have relatively limited applicability for purchaser implementation decisions in the current context.
- Case studies providing anecdotal evidence from adopters.
  We excluded reports of the effects of the adoption of these types of plans by particular organizations if they did not provide adequate information to evaluate the methodology by which the effects were estimated. ^50^ We also excluded studies in which researchers have compiled evidence from this “grey literature”. ^51^ – ^53^ Although many of the studies provide interesting examples, we excluded them because it was not possible either to evaluate the validity of the findings or to determine in what types of settings the findings would be most applicable.
- Prevalence studies that did not indicate the population represented by the study sample.
  This exclusion applied primarily to sources that we identified by following up on references in reviewed articles. One example is a series of studies by America's Health Insurance Plans (AHIP), a national association of health insurers, which is based on surveys of member organizations of HSA enrollment. We excluded these studies due to uncertainty regarding the extent to which they adequately identify the enrolled population.
- Studies identifying the theoretical effects of these types of plans.
  Finally, we excluded studies which identify the theoretical effects of these types of plans, but did not provide original evidence. These studies provide guidance for considering potential effects but only limited evidence for decision makers interested in knowing the actual effects of these plans. ^3,^ ^54,^ ^55^

## Review of Articles Identified

We reviewed the 11 articles identified in the literature search. Table 4 summarizes key features of these articles.

Table 4 Summary of key articles

Reference/Article Category* | Research Question | Data Source | Study Design | Results/Findings | Comments and Conclusions
Summary 1. | “To compare medical care costs and utilization in a consumer-driven health plan (CDHP) to other health insurance plans.” | Health plan administrative records and demographic data from a single large employer that introduced a CDHP in 2001 were linked to health plan cost and utilization data for workers and dependents. | The study sample included a subset of employees (and their dependents) who were assigned to 1 of 3 cohorts: (1) continuously enrolled in a health maintenance organization (HMO), (2) continuously enrolled in a preferred provider organization (PPO), or (3) enrolled in a CDHP in 2001 and 2002, after previously enrolling in either an HMO or PPO in 2000. While employees had a choice between 2 CDHPs, the majority enrolled in a plan with health spending account/deductible threshold combinations of $1,000/$1,500, $1,500/$2,250 and $2,000/$3,000 for single, 2-person, and family contracts, respectively. | The CDHP cohort was healthier, as measured by case mix, and higher income than either the HMO or PPO cohorts in the year prior to enrollment in the CDHP. The case mix in the CDHP deteriorated more rapidly over time than the case mix of the other two plans. | Significantly higher hospital admissions and costs for CDHP cohort in the final year are consistent with 2 possible explanations: 1) enrollees demonstrated significant moral hazard once the deductible was met, and 2) enrollees reduced their use of preventive care which ultimately resulted in higher future expenditures. The study, however, does not provide evidence to identify the cause of higher spending in the CDHP in the final year.
Parente ^56^ | | | The authors present means of demographic, socioeconomic and health status characteristics across cohorts in year 2000, prior to the introduction of the CDHP to assess selection by enrollees into plans. Health status/case mix is measured using diagnosis codes from claims. | Before enrollment in the CDHP, adjusted total expenditures were lower for the CDHP cohort than the other two cohorts. By the second year of enrollment in the CHDP, the CDHP cohort experienced lower adjusted total expenditures than the PPO cohort but higher expenditures than the HMO cohort. | Represents the experience of single employer which may not be representative. In this case, the findings are potentially driven by particular characteristics of the benefit design including a) small gap between PCA and deductible and b) no cost-sharing once deductible met. In addition, the case mix variable, which is linked to claims, may be problematic, particularly as a control for health status in making comparisons over time and across plans in utilization.
O, S | | | The authors compare differences in utilization by calculating regression- adjusted estimates of expenditure and utilization, both total and by category (hospital, physician and pharmacy), for each cohort and each year. Controls include time trend, plan choice and interaction with time trend, age, gender, case mix, health shock, income, covered lives, and use of flexible spending account. | The employer-paid portion of adjusted expenditures was highest for the CDHP cohort in 2002 and employee costs in the CHDP were consistently lower than in the PPO and higher than in the HMO.
| | | | Adjusted hospital expenditures and hospital admissions rose more quickly for the CDHP cohort than the other 2 cohorts during the study period, particularly during the final year.
Summary 2. | “To assess the experience of enrollees in a consumer-driven health plan.” | A 2003 telephone survey of University of Minnesota employees regarding their 2002 health benefits. | Compare enrollee satisfaction with customer services, overall satisfaction, and plan switching behavior between those in CDHPs and those in more traditional plans. The CDHP is the same as in Summary 4 ^57^ . Use multivariate or logistic regression to adjust for differences across plans in enrollee characteristics. | CDHP enrollees were older, equally likely to report a chronic condition, and higher income than enrollees in other types of plans. | The results suggest the CDHPs attract high-income and older enrollees, but provide little evidence of favorable selection based on health status.
Christianson et al. ^57^ | | | Examine use of different CDHP features and assessment of the usefulness of these features among CDHP enrollees. | CDHP enrollees significantly more likely to call customer service and to have a “paper-work experience.” They were significantly more likely to have problems with both. | The results overall indicate less satisfaction among enrollees in the CDHP than enrollees in other types of plans, although the differences are small.
O, S | | | | CDHP enrollees had a significantly lower satisfaction rating but the magnitude of the difference was very small. | The information offered by the CDHP was not widely used by enrollees.
| | | | CDHP enrollees were significantly more likely to switch to a different plan at the end of the enrollment year, although the magnitude of the difference was small. | The limitations of the study are as follows: 1) significant differences between survey responders and non-responders could cause bias; 2) experience represents employees at one firm which may not be representative; and 3) CDHP-enrolled employees are “early adopters” and may not be representative of later adopters.
| | | | 34% of respondents in the CDHP indicated they had used the website with lower proportions indicating they had used it for particular functions. 87% of respondents in the CDHP indicated they would recommend the plan to a friend, 46% indicated they had a particularly positive experience and 24% indicated they had a particularly negative experience.
Summary 3. | To report employers' knowledge, perceptions, and present and future offerings of consumer driven health plans. | 2003 supplement to Kaiser/HRET Survey of Employer-Sponsored Health Benefits, a random sample of 1,856 U.S. firms with three or more workers. | Descriptive statistics, including univariate tables and cross-tabulations. | In 2003, approx. 2% of workers could choose an HRA plus high deductible plan, 4 % in firms with 5000 or more workers. | Employers were very familiar with and showed significant interest in consumer driven healthcare, suggesting possible increased growth in CDHP prevalence in the near future.
Gabel et al. ^9^ | | | Responses to survey questions were weighted to be representative of U.S. employees. | 82% of employers' were familiar with HRA plans and 31% of employee benefit managers reported being either somewhat or very likely to consider offering an HRA plan in the next two years. | Employers were generally skeptical about HRAs ability to control costs and improve consumers' decision- making and quality of care.
P | | | (Survey was in 2003 before MMA authorizing HSAs was signed. CDHP incidence is measured here by an HRA coupled with a high deductible plan.) | HRA plans were about twice as common in large firms as in small firms.
Summary 4. | To determine who chooses a CDHP in a multiplan, multiproduct setting, focusing on whether the CDHP attracts sicker employees. | 2002 data from an employer (University of Minnesota) payroll system supplemented with an employee survey. | Estimated conditional logit models, interacting plan indicators with employee characteristics, to examine the relationship between employee characteristics and the likelihood of choosing the CDHP. Employees could choose from the CDHP, an HMO, a PPO, and a tiered network product based on care systems. | Neither chronic illness nor the employee's age had an effect on the likelihood of choosing the CDHP relative to choosing the traditional HMO. However, the results suggest that the CDHP experienced favorable selection based on both health status and age relative to the PPO. | The results suggest that CDHPs may experience favorable selection based on health status relative to some types of plans but not others.
Parente, Feldman and Christianson ^58^ | | | | Higher income employees as well as those who had a preference for access to a national provider panel or a plan that included their physician in the panel were more likely to choose the CDP than the HMO. | Some people enroll in CDHPs to obtain access to a broader set of providers. This highlights the importance of the specific context in which the CDHP is offered. For example, in this study, people with strong preferences for broader provider access may have preferred the Definity Plan because it provides access to the Mayo Clinic at a lower premium relative to the only other plan that offered this access.
S | | | | | Generalizability is limited by the fact that it was the first year of the plan offering, that relatively few people choose the plan, and the measure of health status was based on self-reported chronic conditions.
Summary 5. | To examine the effect of demographics, health, and stated preferences on the choice of a CDHP and workers' satisfaction with the enrollment process. | 2001 mail survey of 4,680 employees in the corporate offices of Humana Inc. who were eligible for health care benefits. | Employees were offered a choice among 2 HRA-type CDHPs as well as 2 PPOs, an HMO, and an out-of-area plan. | Employees with excellent and very good health (self-reported) were significantly more likely to choose the CDHP than those with worse self-reported health. | At Humana, CDHPs appear to begin with favorable selection.
Fowles et al. ^59^ | | | One CDHP has an allowance of $500, then 80% coinsurance until $2,000 of further out-of-pocket charges were incurred, and finally 100% coinsurance. The other had a $500 allowance, then a $2000 deductible, and finally 100% coinsurance. The plans offered allowances rather than HRAs because the tax-sheltered status of HRAs was unclear when the plans were being designed and implemented. | Employees reporting greater utilization (receiving treatment for chronic condition, physician visit in past 4 weeks, have a personal physician) significantly less likely to choose CDHP. | Experience only of a single employer may not be representative. In this case, the CDHP provider network was “unusually restrictive” and there was no ongoing internet support or decision tools for enrollees. Plans were new and first year enrollment may not be indicative of longer term trends.
S | | | The primary outcome of interest was employee's self-reported choice of a health plan. The authors estimated a logit model of the choice of either one of two offered CDHP plans versus any of the other plans offered. | Blacks, non-exempt workers significantly less likely to choose CDHP.
| | | Covariates include gender, education, race, self-reported health status, health care utilization, and stated preferences, among others. | Employees reporting “lowest premium” as most important plan characteristic significantly more likely to choose CDHP.
Summary 6. | “To determine whether the offering of a consumer-directed health plan (CDHP) is likely to cause risk segmentation in an employer group.” | Administrative data from Humana, Inc. on approximately 10,000 covered employees and dependents from benefit years beginning July 1, 2000 and July 1, 2001. | The company offered 3 plans (2 PPOs and 1 HMO) in the first year of the study, and added 2 CDHPs in the second year. The CDHPs both had $500 HRAs, but differed in their cost sharing and employee premium contributions. Funds in the HRA could NOT be rolled over and could only be applied to utilization within a specified network of providers. | Most enrollees in the CHDPs had previously enrolled in a PPO. | “Offering a consumer-directed plan alongside traditional HMO and PPO coverage led to risk segmentation.” The CDHP plans attracted healthier members.
Tollen et al. ^60^ | | | Comparisons of average demographic characteristics and prior use claims data for each of the five plans offered by Humana beginning July 1, 2001. Claims for PPO enrollees are likely to be underreported due to unavailability of claims for both out-of-network utilization and utilization prior to reaching the deductible. | Demographic comparisons do not show any clear pattern of segmentation. | Claims data were required to see this selection; it was not evident from demographic comparisons.
S | | | Comparisons were also made specifically for prior Rx claims since the Rx plan was similar across all offered plans and would therefore be less affected by differences in benefit design. | CDHP members had higher average income. | The findings represent the experience of a single, early adopting firm. The Humana arrangement differed from many others in that the HRA was not allowed to rollover and the provider network of the CHDP was relatively restrictive. In addition, there were many simultaneous changes in the benefit package.
| | | | Claims data show favorable selection into CDHP. For example, prior year Rx claims for CDHP enrollees were approximately 50% of the mean of all enrollees. | Some of the analyses are biased toward finding evidence of favorable selection based on health status into the CDHP. This is because the CDHPs drew most heavily from the PPOs, and utilization was under counted in the PPO.
Summary 7. | To examine the prevalence of consumer-directed health plans and the extent of decision support in such plans. | Survey of 680 health plans (986 products) by Mercer Human Resource Consulting in 2003, including supplemental questions specific to consumer-directed benefits. | Tabulations of survey data. | 3% of surveyed health plans reported offering CDHPs with positive enrollment in 2003, enrolling a total of approximately 466,000. | High growth in enrollment in CDHPs; “nonetheless, projections attributed to industry insiders such as ‘20 percent of the market by 2005,’ are difficult to reconcile with our survey responses.”
Rosenthal and Milstein ^1^ | | | (CDHP, as defined in this literature review, corresponds to Rosenthal and Milstein evidence on Health Reimbursement Account Models (again, prior to MMA authorization of HSAs)). | Modal HRA dollar amount was $1000 (mean $824) and modal deductible $1500 (mean $1654). Standard deviations not reported. | “Plans that specialize in offering HRA models still dominate the HRA market, although to a lesser degree than previously reported.”
P | | | | Greater decision support services in the CDHP plans than in tier-benefit models. For example, quality information on individual physicians or groups was available to 91% in CDHPs but only 9% in tiered models. | Survey had 70 percent response rate but some plans may not have been identified or contacted by Mercer. Prevalence may therefore be somewhat underestimated.
Summary 8. | To study the characteristics of tax filers reporting MSA enrollment and the effect of characteristics such as income on MSA enrollment. | IRS tax return data from 1997-2001. | Descriptive statistics on the characteristics of the universe of tax units reporting MSA enrollment. | By tax year 2001, only 247,041 different tax units had ever reported having an account. Approximately 25% of tax filers reporting MSA enrollment reporting being uninsured for the prior 6 months. | The results suggest that MSAs were disproportionately chosen by high income individuals.
Minicozzi ^61^ | | | Probit model of MSA enrollment for self-employed tax filers in 2001. | “In any given year, most taxpayers withdrew less than 60% of what they contributed, but about one-fifth withdrew at least 90%.” | While analysis of the relationship between demographic characteristics and MSA holding does not provide clear evidence of favorable selection (middle-aged were more likely than younger individuals to have an MSA), analysis of differences in health insurance premiums for MSA holders and other insured self-employed individuals provides evidence of favorable selection.
S, O | | | OLS model of the effect of MSA/high deductible plan on plan premiums. | Income positively associated with MSA account duration. | Long-term MSA account holders built balances suggesting “that there is also a savings component to HSAs.”
| | | | For the self-employed, the probability of choosing an MSA is lower for below-median income and for those over 55 but higher for tax filers between 45 and 55. Marginal tax rate is not significant once income is controlled for. | The case of MSAs may not be representative of more recent CDHP developments because 1) MSA regulations allowed either employee or employer, but not both, to make contributions, and this may affect account balances and saving; and 2) MSAs were restricted to small employers and the self-employed. In addition, some of the analyses in the paper focus on the self-employed who may not be representative.
| | | | “MSA holders have policies that cost an estimated 40.5% less” than policies of self-insured filers who do not have MSAs. Based on American Academy of Actuaries estimates the higher deductible should account for, at most, a 30% lower premium, suggesting favorable selection into MSAs.
Summary 9. | To investigate the early experience of first-generation consumer-directed health plans and the suitability of their design for reducing the growth in health benefit spending and improving the value of that spending. | Case studies of 14 consumer-directed health plans. | Definition of consumer-directed health plans is a plan that includes 1) enhanced tools to support informed choice of providers and treatments; 2) expansion of programs to enable consumers to manage their health and health care; and 3) stronger financial incentives for consumers to control spending. | Summarized results restricted to those relevant to spending account plans. | Illustrates the wide variety of CDHP benefit design features available in the market.
Rosenthal, Hsuan and Milstein ^2^ | | | Examined both spending account and tiered consumer-directed plan models. | Most of the spending account plans reported internal estimates of reduced service use and total spending because of the introduction of the new models. Plans attributed most savings to service substitutions by consumers rather than reductions in overall rates of service use. (However the methods used to derive this information are not presented in detail.) | Does not provide evidence of how specific CDHP design characteristics affects outcomes.
| | | Plans included 7 spending account models, 3 premium-tiered models, one premium-tiered customized-benefit design model, and 3 point-of-care tiered models. Did not include HSAs since they had newly entered the market. | Several spending account plans reported annual renewal frequency above 90 percent both employers and employees with a choice of plans.
| | | Prioritized plans with larger market share and those operating for at least a year. Included plans serving large (mostly self insured) and small (mostly fully insured) employers. Analyzed the implementation of each plan for a specific employer. Interviewed the plan's medical director or marketing executives and the employer's human resource or health benefits director. Asked questions in 6 categories: 1) targeted purchasers; 2) benefit design; 3) consumer decision support and health/health care management; 4) quality of care/ financial protections; 5) observed risk segmentation effects among enrollees; and 6) impact on enrollees' satisfaction, reenrollment rates, services use, plan-paid costs, out-of-pocket costs, and provider behavior. | No plans adjusted cost sharing by income of enrollee.
| | | | Only 2 spending-account plans provided any provider-specific cost information and this was limited to unit price.
| | | | Spending account plans undertook engaging consumers in their managing their own health through the use of nurse-staffed telephone help lines (100%); health risk assessment linked to staffed risk reduction programs (>80%), shared decision support/health coaching (>60%), and case management (100%).
Summary 10. | To provide national data regarding the growth of high-deductible health plans with and without savings accounts and their impact on the behavior and attitudes of health care consumers. | Randomly chosen sample from Harris Poll Online, Harris Interactive's online sample of Internet users who have agreed to participate in research surveys. Adults with high-deductible health plans both with and without HSAs or HRAs were oversampled (>=$1,000 for single coverage and >=$2,000 for family coverage). Individuals were surveyed in October 2005. | Descriptive statistics based on survey data. Consumer-driven health plans (CDHPs) were defined as high deductible plans with a spending account. High deductible health plans (HDHP) were defined as high deductible plans that were eligible for, but did not have, savings accounts. | - 1% of the privately insured population ages 21–64 were enrolled in CDHPs and 9% were enrolled in HDHPs. | As of Oct. 2005, a small proportion of the population had a high deductible health plan and even fewer had health savings accounts.
Fronstin and Collins ^62^ | | | | - Individuals in CDHPs and HDHPs are less satisfied than individuals with comprehensive health insurance with their health plan and are less likely to recommend the plan to a friend or work colleague. | People in these plans are less satisfied with their coverage, report higher levels of out-of-pocket spending, and report more financial related constraints on utilization than those in more generous coverage.
P, S, O | | | | - People with CDHPs were slightly more likely to be in excellent or very good health than those with comprehensive health insurance though the percentage of people reporting a health problem (either particular condition or fair or poor health) was similar across the 3 groups. Those in CDHPs were less likely to be obese and those in both CDHPs and HDHPs were less likely to smoke and more likely to report exercise. Those in CDHPs were higher income than those in the other 2 groups. | People in these plans report similar levels of health care utilization as those in more generous plans.
| | | | - Little difference across health plans in self-reported health care use, although individuals enrolled in CDHPs and HDHPs are more likely to report than they had avoided, skipped, or delayed health care due to costs. | Relatively little information is available on provider quality.
| | | | - People with CDHPs and HDHPs were more likely to spend a large share of their income on out-of-pocket health care expenses than those in comprehensive plans. | There is evidence of favorable selection into CDHPs and HDHPs for some, but not all, health measures.
| | | | - Individuals in CDHPs and HDHPs exhibit more cost-conscious behavior in their health care decision making than individuals with comprehensive insurance.
| | | | - Individuals in all 3 types of plans were about equally likely to report that their plan provided provider cost and quality information but those in CDHPs and HDHPs were more likely to report that they had used the information.
Summary 11. | To document the availability, enrollment, premiums, and cost sharing for high-deductible health plans that are offered with HRA or HSA qualified plans. | A 2005 survey of employer health benefits conducted by Kaiser/HRET based on a random sample of firms with 3 or more workers. | A high deductible health plan (HDHP) is defined as a health plan option that has a deductible of at least $1,000 for single and $2,000 for family coverage. | 1/5 of employers offering health benefits offered a high deductible health plan. Jumbo firms (5,000+ workers) were more likely than smaller firms to offer and HDHP. About 4% of firms offering a HDHP offered either and HRA with the plan, and HDHP that is HSA-qualified or both. | Results are not necessarily comparable to earlier KFF/HRET employer surveys due to changes in the questionnaires.
Claxton, Gabel et al. ^63^ | | | | Nearly 4% of employers that offered health benefits offered one of these arrangements. Deductibles average $1,870 for single and $3,686 for family coverage in HRA plans and $1,901 for single and $4,070 for family coverage in HSA-qualified plans. 1 in 3 employers offering an HSA qualified high-deductible health plan do not contribute to workers' HSAs. | One explanation for the relatively low offer rate of HSA-qualified HDHPs is that although they were authorized in 2003, the Treasury Deparment didn't issue regulations for the implementation of HSAs until summer 2004. This might have discouraged emploers from offering HSA-qualified HDHPs in 2005.
(P) | | | | 1.6 million employees are enrolled in HDHPs with an HRA - representing more than 2% of covered workers.
| | | | 810,000 workers are covered by an HSA-qualified HDHP offered by their employer - about 1.2% of covered workers.

* Category:

O = Outcomes (Cost, Quality, Expenditures, Satisfaction)

S = Selection

P = Prevalence

## Conclusions From Literature Review

### Summary of Evidence Available in the Existing Literature

The existing literature published literature on CDHPs is limited in size and scope in some important ways, and not fully able to address the research questions of strongest interest. Nonetheless, the available evidence does provide useful information about the performance of some CDHPs in some dimensions, albeit with a number of limitations. This section summarizes the information that is available in existing literature. The next section outlines key limitations in the current literature.

- CDHP's Experience Favorable Selection (at Least in the First Round)
  Most of the studies that have examined worker choices among plans at firms that offered a choice of plans including a CDHP have found favorable selection in a number of dimensions for the CDHP relative to one or all of the other offered plans. Evidence of favorable selection based on income is particularly strong: higher incomes are found to be associated with CDHP choice by authors listed above in Table 3.4, Summaries 1, 2, 4, 6, and 11.
  The research also tends to find, although not unanimously, favorable selection by health status. For example, in Summary 1, Parente et al. find initial favorable CDHP selection based on their case mix measure. Fowles et al. (Summary 5) report that employees with excellent and very good self-reported health were more likely than those who reported worse health to choose the CDHP. Fronstin et al. (Summary 10) find that, although there are only small differences across plan types in self-reported health, CDHP enrollees are less likely to report being obese, less likely to report that they smoke, and more likely to report regular exercise than those in more comprehensive plans. However, Christianson et al. (Summary 2) find no significant differences in self-reports of health by type of plan. Tollen et al. (Summary 6), using the less subjective measure of Rx claims in the year prior to enrollment, find that Rx claims for (future) CDHP enrollees were approximately 50 percent of the mean of all enrollees, though their simple demographic comparisons did not show evidence of any segmentation. Parente et al (Summary 4) distinguish between types of plans and find no evidence of selection against the HMO plan but favorable selection for the CDHP by health and age relative to the PPO plan. Indirect evidence of favorable selection into MSA/high deductible plans is provided by Minicozzi (Summary 8) based on lower premiums for MSA plans than American Academy of Actuaries estimates would be warranted simply due to their lower deductibles.
  Although the evidence of favorable selection is relatively strong, some caveats must be kept in mind. Because of data limitations, most of these studies report results based on only one year of CDHP experience. CDHP early adopters may have different characteristics than later adopters. Perhaps more importantly, the CDHP experience itself may also affect selection either as enrollees leave the plan or experience different outcomes or incentives over time. In fact, one study does provide evidence of changes in the composition of the CDHP population over a two-year period. While Parente et al. (Summary 1) report initial favorable selection for the CDHP, the case mix in the CDHP deteriorated more rapidly over time than the case mix of the other two plans. In addition, as we also discuss below, the degree of selection may be affected by aspects of the benefits design such as the breadth of the provider network. Of these early studies, for example, Fowles et al. (Summary 5) point out that the Humana CDHP network was “unusually restrictive,” while Parente et al. (Summary 4) suggest that the employees in their study may have been attracted to the CDHP because of its access to providers at the Mayo Clinic. The stronger favorable selection found at Humana could therefore be due to the restrictiveness of the provider network, relative to the network of the plan in the Parente study. Finally, selection issues are likely to be most prominent when there are multiple plans to choose from, and will depend on the specific choice sets available where there is choice. Extrapolation of this evidence to other settings where there may not be other choices, or may be different choices, would be difficult.
- There are Frequent Reports of Lower Expenditures in CDHP's but More Convincing Evidence is Needed
  Most of the reported evidence on the effect of CDHP's on health care expenditures suggests that expenditures are lower in CDHP's than in more comprehensive plans. In most cases, however, these reports do not provide strong evidence, primarily because it is difficult to assess the methods used to identify the cost savings. ^2,^ ^52^ One important exception is the finding by Parente et al. (Summary 1) that by the second year CDHP enrollees had substantially higher hospital expenditures and admission rates than enrollees in the other plans. They suggest that this could be due to moral hazard once the deductible was met or reduced use in prior years of preventive care which ultimately resulted in higher expenditures. The study does not provide evidence to identify which, if either, of these explanations is correct. Finally, Fronstin and Collins (Summary 10) provide somewhat conflicting evidence. While they find little difference between individuals enrolled in CDHPs health plans in self-reported health care use, they also find that individuals enrolled in CDHPs and HDHPs are more likely to report than they had avoided, skipped, or delayed health care due to costs. In summary, strong evidence on the effects of CDHPs on utilization and health expenditures is sparse and the evidence that exists is somewhat conflicting.
- Satisfaction with CDHP's Appears Lower but Lack of Understanding due to Newness of Plans Could Be the Cause
  There is some evidence that CDHP enrollees are less satisfied with their health plan than enrollees in other types of plans. For example, Christianson et al. (Summary 2) report a very small but statistically significant lower overall satisfaction rating for CDHP enrollees than those in other plans. Fronstin and Collins (Summary 10) report larger differences, with CDHP enrollees again being relatively less satisfied with their plan. It is also important to note that the University of Minnesota employees surveyed in Christianson et al (Summary 2.) had a choice of health plans that included a CDHP, while the respondents to the Commonwealth Survey reported on in Claxton and Gabel et al. (Summary 11) may or may not have had a choice among plans.
  As Christianson et al. (Summary 2) point out, it is difficult to know how to interpret small differences in satisfaction. They consider, on the one hand, the possibility that early-adopters might be expected to be more satisfied with the plans. But, they also raise the important point, given the newness of these plans, that “some who selected this new option may not have fully understood its implications and therefore could be expected to rate the plan poorly.” Long-term measures of satisfaction could well differ from these early reports if a substantial number of CDHP early enrollees were not well informed prior to their choice.
- One Study Provides Evidence that CDHP Precursor (MSA+High Deductible Plan) Enrolled the Previously Uninsured
  There is very little evidence as to whether CDHP-type plans are providing viable insurance options to those who would otherwise have been uninsured. However, one study does provide some evidence that, in the case of MSA-type plans, a CDHP precursor, this is the case. Using tax return data, Minicozzi (Summary 8) reports that approximately 25 percent of tax filers reporting MSA enrollment also reported being uninsured for the prior 6 months. Minicozzi reports substantial non-response on the question of prior insurance status which could affect this conclusion. When evaluating this evidence, it should be noted that one would expect some fraction of the individuals purchasing any type of insurance to have been formerly uninsured, and it is not clear whether the share reported here is higher or lower than might be found for other types of insurance.
- Benefit Design Specifics Matter but No Evidence Yet About Optimal Design
  Several studies provide suggestive evidence that specific aspects of the CDHP benefit design may have important consequences for outcomes ranging from expenditures to selection. However, none of these studies tests the effects of particular aspects of benefit design, such as the size of the deductible, size of the “doughnut hole,” or copayment levels, due to lack of appropriate data. Estimating the effects of plan characteristics and providing convincing evidence on optimal plan design will require data on outcomes for CDHP enrollees enrolled in plans with variation in these characteristics as well as some way to account for possible differential selection into plans with varying characteristics.
  Suggestive evidence that particular design characteristics matter is provided by several of the reviewed studies. For example, Parente et. al. (Summary 1) suggest that their finding of dramatic increases in expenditures for CDHP enrollees in year 2 over year 1 could be a result of a very small “doughnut hole” (especially once there were rollover funds from the previous year) and no coinsurance once the deductible was met. Parente et al. (Summary 4) and Fowles et al. (Summary 5) suggest that the restrictiveness of the provider network may influence the degree of selection experienced by the CDHP, and a comparison of their results supports this interpretation. Fowles et al. report both a much more restrictive network and much more favorable selection as compared to the results of Parente et al. Although Fronstin and Collins (Summary 10) illustrate that there are a wide variety of plans with substantial variation in plan characteristics, none of the studies had access to detailed data on CDHP plans with varying characteristics and thus none estimated the effects of changing plan characteristics.

### Gaps in Existing Literature

Several important gaps in the existing literature were pointed out in the previous section. Perhaps the most important general source of those limitations is the fact that existing literature is focused on a small number of cases. Since the effects of CDHPs are likely to vary substantially with their circumstances, it is thus difficult to compare existing studies and very difficult to draw generalized lessons that could be applied to predict the effects of new implementations. In addition, existing literature has not addressed the full range of treatment, cost, and outcomes that may be of interest, including important questions about the relationships between CDHPs and quality improvement, access to care, the use of needed vs unneeded care, and health outcomes. It seems likely that these gaps exist largely because of the early stage of development of this literature. We expect that as the literature develops further these gaps will be narrowed.

Some of the questions put forward at the outset of this project concerned the ability of the literature to support comparisons between different consumer-oriented approaches. For example, one might wonder whether the more useful strategy is to adopt a CDHP or introduce tiered networks into other types of health plans. Or, one might wonder about synergies between different strategies, such as a comparison of the potential effects of a CDHP alone as opposed to a CDHP in conjunction with expanded provider quality data collection and dissemination. Our review of existing literature found no instances of empirical studies that evaluated the effects of CDHPs relative to other types of consumer-oriented strategies. We also found no studies that provide a basis for drawing conclusions about the differential effects of CDHPs with and without expanded quality data collection and dissemination, or about other synergies between CDHPs and consumer-oriented strategies.

Existing literature is also insufficient to develop guidance about the optimal parameters for CDHP design, such as the optimal level at which to set the deductible, the optimal contributions to the PHA, or other features.