# A Conceptual Model

The impact of consumer-oriented health plan strategies such as CDHPs, tiered networks, and improvements in the collection and dissemination of provider quality information will, in principle, be determined by a number of factors. In this section, we discuss a range of factors that are expected to be important determinants of their ultimate effects. We consider two types of factors. First, the consumer-oriented strategies we study manipulate features of health benefits in ways designed to change the economic incentives consumers face, or the information available to them, when they make health care decisions. CDHPs, for example, change the prices facing consumers in certain spending ranges. These changes are expected to have impacts on the decisions of patients and providers. We term the central changes in benefits or information availability that are brought about by the use of these strategies as the “core mechanisms” by which they work.

Second, the impact of the core mechanisms would be affected by the context within which they operate. The importance of the overall financial and non-financial aspects of the setting within which decision making agents act to the impact of any given set of specific incentives has been discussed previously. ^16^ – ^18^ Hellinger concludes from a review of the effect of managed care on quality that assesement of any management strategy, which would include these kinds of benefit design changes, requires detailed information about the characteristics of health plans, providers, and enrollees to draw conclusions. ^16^ Hutchison et al. point to the importance of considering the context in which financial incentives are designed or implemented to understand their potential effects. ^17^ Dudley et al. show how incorporating contextual factors into their conceptual model of quality based purchasing can shed important light on the functioning of financial incentives in different situations. ^18^

To our knowledge, no conceptual model of the factors influencing the impact of specific benefit design changes considered here has been proposed. The model we propose incorporates both the core set of incentives targeted by benefit design changes and incorporates important aspects of the context within which they operate.

## Adapted Andersen Framework

The aim of CDHPs, tiered networks, and improved collection and dissemination of provider quality information is to influence decisions made by patients and their health care providers about the use of different types of care. It is these utilization decisions that ultimately determine the impact of benefit design changes on the quality and cost of care.

From the perspective of an individual patient facing a situation that could give rise to the consumption of health care, the Andersen framework ^19^ provides a valuable foundation (Figure 2). The classic implementation of this framework considers a patient's response to an illness. Patients are conceptualized as responding to stimuli - the illness onset - that creates a “need” to take action. Whether they take action and what type of action they ultimately take is mediated by “predisposing factors” that influence their desire to respond to the stimulus, and “enabling factors” that influence their ability to respond to the stimulus. Patients ultimately arrive at the point of either using or not using services that, in turn, influence their health status.

Figure 2. Andersen Model

The general framework presented in this model is a useful point of departure for the development of an adapted model that can incorporate many of the important features important when assessing consumer-oriented strategies. In our adapted version of the model (Figure 3), patients may respond to any number of events that might produce an impulse toward seeking interaction with the health care system. The extent to which they do is influenced by mediating factors, which may include economic factors as well as other things. In our application, it can sometimes be unclear which factors are predisposing and which are enabling, in the classic sense of the Andersen model, so we simply retain the category of mediating factors. From the standpoint of assessing consumer-oriented strategies, we expect three factors to be particularly important mediators: the price of services, the ease with which they can access services and the types of services most easily accessible, and the availability of information. These factors will influence the response the individual ultimately makes to the stimulus. In this setting, the principle choices affected are expected to be whether or not the patient seeks any interaction with the system, which providers are consulted, and which services are ultimately received from those providers. These, in turn, determine the spending and outcomes.

Figure 3. Adapted Andersen Model

## Core Mechanisms

### Prices of Services

The central focus of CDHPs and tiered networks is on changing the prices that consumers face for purchasing health care services. Economic theory clearly predicts that the price facing consumers can influence the number and type of services they consume, and empirical evidence confirms this prediction. ^20,^ ^21^ Evaluating the impacts of price changes will require understanding both the size of the price changes and the strength of the response to price changes. Fully understanding the size of the price changes brought about by consumer-oriented strategies may be challenging. While a goal of CDHPs is to raise the prices facing consumers for some of their health care spending, the amount by which prices change will vary with the provisions of the CDHP and the situation from which consumers are moving (i.e., the health plan to which the CDHP is being compared). As discussed in the previous section, CDHPs would not be expected to increase prices at all levels of spending, and may, in fact, lower effective prices in some ranges.

In tiered networks, the relevant comparisons are the prices that are charged for access to providers in different tiers. These price differences would typically be relatively clearly delineated by the plan in the form of copayment amounts or other cost sharing differences associated with using providers in different tiers (though there could still be differences in the baseline prices charged by different providers, which could also affect the price paid).

The strength of the response to price changes is the second key component of evaluating the ultimate effect of a price change. Economic analyses of price responsiveness often focus on the “price elasticity of demand,” which is a measure of how responsive consumption of a given service is to a change in price. Demand for services that are “price-inelastic” responds relatively little to price changes, whereas demand for “price-elastic” services responds more strongly. Price elasticities can vary from service to service, and from consumer to consumer, so that evaluating the impact of consumer-oriented strategies may require knowing which services, and which consumers, are of primary interest. The effects of a price change in CDHPs could, for example, affect the use of preventive care differently than the use of acute care because the price elasticities differ. ^22^

The interaction of price effects and the appropriateness of services gives rise to some of the important questions about the impacts of CDHPs on health care delivery and outcomes. Consumers will tend to use health care services for which the benefits they perceive they will obtain exceed the price, in money or time or other goods that they will pay to obtain it. If CDHPs increase the prices that consumers face, some services that would have been consumed at lower prices may now not be consumed. Some observers worry that consumers may not value services like preventive care sufficiently highly, and thus may decide to forego these services under a CDHP if preventive care is subject to the deductible. More generally, an important concern about CDHPs is the extent to which they may cause consumers, who may undervalue some services, to forego appropriate care from which they would benefit.

It is also worth noting that price effects can influence more than just the product whose price changes. Consumption of products that are substitutes or complements of the product that had its price changed could also move in response to price changes.

### Provider Access

Patient choices of providers are also expected to be influenced by the restrictions that their plan places on provider choice. HMOs, for example, usually tightly regulate the set of providers that their members can see and have their care covered by the plan. HMOs also often require primary care physician referrals before specialists can be consulted. PPOs also often place some constraints on patient choices of providers. Many CDHPs, on the other hand, place less emphasis on patients using particular sets of providers than other types of plans, even going so far as to impose no restrictions on provider choice or direct access to specialists. Understanding the impacts of consumer-oriented strategies, and CDHPs in particular, would require understanding the provider access provisions under the consumer-directed plan as opposed to a comparison plan.

As with prices, the ultimate effect of changes in provider access depends not only on the extent of the changes in provider access, but also on the extent to which consumers respond to the changes. Some consumers may exhibit stronger responses than others. For example, consumers with long standing relationships with providers may not change providers as quickly as consumers without such relationships. Some services may be more amenable to provider search than others.

### Availability of Information

Information about the price and quality of different treatments and providers would be expected to improve the ability of consumers to make informed decisions and enable them to make trade-offs between cost and quality. Whether an individual seeks information depends on the costs and benefits of obtaining this information. ^23^ By increasing the out of pocket cost associated with seeking care, consumer-driven strategies would likely increase the extent to which individuals seek information on the costs and quality of health care. ^24^ Because the benefits and costs of obtaining information vary across individuals, we would also expect differences across individuals in the extent to which they use these resources. ^25^ For example, those who are in worse health would be more likely to use information resources because the expected benefits would be greater. The effect of education, in contrast, could be mixed. While the costs of accessing information in this setting may be lower for those with higher levels of formal education, the benefits of information resources may also be lower. This is because they may have been better informed in the absence of the information tools provided by the health plan. Finally, the extent to which information influences treatment patterns will depend on the quality of information available. If these resources are difficult to use or provide consumers with relatively little new information, we would expect them to have relatively little impact on decision-making.

## Contextual Factors

The adapted Andersen model provides a valuable way of conceptualizing the ways that core forces associated with the policy instruments under consideration can influence decisions about health care use. The insights gained by simply considering these factors are important. In fact, many discussions of CDHPs, tiering, and quality information provision get no further than these core plan features. However, going no further than the core mechanisms would leave out crucial information. In particular, the context within which the core mechanisms operate may have a very important impact on how effectively they function. Incorporating contextual information adds important nuance to the narrow core concepts and emphasizes the importance of context for assessing the contributions of existing empirical evidence. We focus on two key types of contextual factors: the types of consumers who end up in different health plans, and the effects of the health care market context within which health plans operate.

### Selection

In settings where there are choices of different health plans, or choices of whether or not to join a plan, questions about selection can arise. In this context, one key group of contextual factors thus concerns the groups of people who end up in health plans with different features in settings with some choice. The way an individual will respond to any given stimulus like an illness onset may vary in magnitude according to the characteristics of the individuals making the decision (Figure 4). For example, economic theory would predict that moving people from a standard PPO into a CDHP will tend to raise the prices they face for some of their routine medical care and thus lead them to tend to use less care. However, price effects may be stronger for lower income individuals than higher income individuals, or for persons with mild conditions compared to those with (what at least seem to them like) more pressing problems. If CDHPs or tiered network plans in particular attract individuals that disproportionately reflect certain demographic or health characteristics, the effects of benefit design changes in the CDHP-covered population may be different than might be expected in the general population.

Figure 4. Adapted Andersen Model with Selection Characteristics

Similarly, the provision of information about quality of care may differentially influence consumers with different health problems, different levels of experience with other health care providers, different levels of education, or other variations in characteristics.

There may also be differences in the rate at which different populations experience the onset of an illness, the occurrence of an injury, or other stimuli. Healthier populations need to see physicians less frequently than sicker populations. If the groups of individuals who join CDHPs or tiered network plans have, on average, different characteristics or preferences than those who do not, there could be differences in the number and type of stimuli experienced in the enrolled population compared to the general population. This could, in turn, lead to variations in health outcomes or expenditures that are unrelated to the specific incentives that are incorporated into the plan.

The characteristics of individuals who ultimately end up enrolled in CDHPs or tiered network plans will be a function of decisions at a number of levels. Achieving a full understanding of the ways that CDHPs and tiered networks could affect care, costs, and outcomes would require investigating the various factors that would affect selection outcomes at each level. Though a complete discussion is beyond the scope of our undertaking here, some key points are evident.

For many Americans, choices by an employer about which plans to offer will determine whether or not they have a realistic choice of joining a CDHP or a plan with a tiered network plan. Economic theory argues that employer choices will be affected by the premiums charged by health plans in their choice set and the benefits they offer as well as the types of workers employed within a firm. ^26^ Some employers may find the price-benefits tradeoff more attractive than others, and thus it does not seem likely that all firms will be equally likely to offer CDHPs or tiered networks.

At a second level, employees of firms that offer CDHPs or plans with tiered networks along with other plans will make decisions about whether or not to enroll in the plans using consumer-oriented strategies. This will be a function of the costs and benefits of joining these plans, relative to other options. Economic theory suggests choices will be influenced by factors such as the types and characteristics of other plans available, the total premiums charged and the amount of premium paid by the employee out of pocket, consumers' expectations about their healthcare utilization and information about the quality of different plans. ^27^ – ^30^ Different employees would be expected to view these cost and benefit tradeoffs differently, and thus one would not necessarily expect uniform patterns of enrollment in CDHPs across employees in different circumstances.

### Market Factors

The impact of benefit design changes will also vary with the features of the insurance and health care delivery market (Figure 5). For example, the number and organization of physicians and hospitals in an area will affect the ways that individuals respond to the incentives in their health plans. Market characteristics may also affect selection into plans. The presence of more or less competition between insurers, for example, may affect the characteristics of competing plans and premiums, which may influence who enrolls in which plans.

Figure 5. Adapted Andersen Model with Market Forces

It may also be that there are important relationships between the adoption of CDHPs and tiered networks and the characteristics of the insurance and health care delivery markets. Increasing enrollments in CDHPs in an area may, for example, favor some types of physicians or some ways of arranging provider networks over others ultimately leading to changes in delivery system structures.

### Adequacy and Value of Available Information

The extent to which information about quality of care, prices, or other important factors is easily available and of high quality is likely to be a determinant of the extent to which information can serve as a mediator and the ways in which it does so. Information that is perceived to be of high quality and that is easily accessible seems more likely to mediate decisions about the use of services than lower quality, less accessible information. In addition, the ways that information is presented may also be important. Information that is presented in ways that consumers find informative and salient may have stronger impacts.

## Interactions Between Consumer-Oriented Strategies

In practice, consumer-oriented strategies are often considered in combinations, either in a comparative framework in which questions about the relative strength of one type of consumer-oriented strategy relative to another are considered, or in the context of attempts to adopt multiple consumer-oriented strategies that would work well together. Indeed, in the long run developing packages of strategies would seem to be a sensible approach since some strategies seem naturally inclined to work together. Principally, improvements in the collection and dissemination of quality information would seem to be very complementary to the use of CDHPs or tiered network strategies.

## Conclusions From the Conceptual Model For Literature Evaluation

One central conclusion of the conceptual model for literature evaluation is that one consumer-oriented strategy need not be the same as the next. CDHPs could vary in their exact provisions and their interaction with other strategies, as could tiered networks or attempts to improve provider quality data collection and dissemination. Understanding the ways that the specific characteristics of consumer-oriented plans influence outcomes will require amassing evidence that compares plans across a range of characteristics. Studying the effects of a given consumer-oriented plan seems likely to provide some, but only some, information about how a different consumer-oriented plan would perform.

A second conclusion is that context is likely to have an important impact on the effects that consumer-oriented strategies ultimately have on health care delivery, costs, and outcomes. The effects that adoption of a CDHP has in one setting may be quite different from effects in other situations. Several aspects of context seem important, including the types of people who enroll in the plans, which will be determined by the types of employers who offer CDHPs, whether they offer only a CDHP or offer a CDHP along with other plans (and if so the number and types of other health plan choices they make available), and the health care market setting in which the plan is offered. Because of the importance of context, studies of consumer-oriented plans in one setting may provide only limited information about how a similar plan would perform in a different setting.