# References

1 Perrin JM, Shayne MW, Bloom SR. Home and Community Care for Chronically Ill Children. New York: Oxford Press; 1993.
2 Stein R. Caring for Children With Chronic Illness: Issues and Strategies. New York: Springer; 1989.
3 Epstein SG, Taylor AB, Halberg AS. Shared Responsibilities: Ensuring Quality Managed Care for Children with Special Health Care Needs. Boston: New England Serve; 1998.
4 Family Voices. What do Families Say about Health Care for Children with Special Health Care needs in California: Your Voice Counts. Boston: Family Voices at the Federation for Children with Special Health Care Needs. 2000.
5 National Health Interview Survey 2000-2003. National Center for Health Statistics, Centers for Disease Control.
6 Hedley AA, Ogden CL, Johnson CL, Carroll MD, Curtin LR, Flegal KM. Prevalence of overweight and obesity among US children, adolescents, and adults, 1999-2002. Jama. Jun 16. 2004;291(23):2847-50. [pmid: 15199035].
7 Costello EJ, Mustillo S, Erkanli A, Keeler G, Angold A. Prevalence and development of psychiatric disorders in childhood and adolescence. Archives of general psychiatry. Aug. 2003;60(8):837-44. [pmid: 12912767].
8 Newacheck PW, Halfon N. Prevalence and impact of disabling chronic conditions in childhood. American journal of public health. Apr. 1998;88(4):610-7. [pmid: 9551003]. [pmcid: 1508436].
9 Wise PH. The transformation of child health in the United States. Health affairs (Project Hope). Sep–Oct. 2004;23(5):9-25. [pmid: 15495347].
10 McPherson M, Arango P, Fox H, et al. A new definition of children with special health care needs. Pediatrics. Jul. 1998;102(1 Pt 1):137-40. [pmid: 9714637].
11 Perrin EC, Newacheck P, Pless IB, et al. Issues involved in the definition and classification of chronic health conditions. Pediatrics. 1993;91:787-93. [pmid: 8464668].
12 Stein RE, Bauman LJ, Westbrook LE, Coupey SM, Ireys HT. Framework for identifying children who have chronic conditions: the case for a new definition. J Pediatr. Mar. 1993;122(3):342-7. [pmid: 8441085].
13 Bethell CD, Read D, Brockwood K. Using existing population-based data sets to measure the American Academy of Pediatrics definition of medical home for all children and children with special health care needs. Pediatrics. May. 2004;113(5 Suppl):1529-37. [pmid: 15121922].
14 Kaye N, Curtis D, Booth M. Certain Children with Special Health Care Needs: An Assessment of State Activities and their Relationship to HCFA's Interim Criteria. Washington, DC: National Academy for State Health Policy; 2000.
15 Ellis RP, Pope GC, Iezzoni L, et al. Diagnosis-based risk adjustment for Medicare capitation payments. Health care financing review. Spring. 1996;17(3):101-28. [pmid: 10172666].
16 Kronick R, Dreyfus T, Lee L, Zhou Z. Diagnostic risk adjustment for Medicaid: the disability payment system. Health care financing review. Spring. 1996;17(3):7-33. [pmid: 10172665].
17 Neff JM, Sharp VL, Muldoon J, Graham J, Popalisky J, Gay JC. Identifying and classifying children with chronic conditions using administrative data with the clinical risk group classification system. Ambul Pediatr. Jan–Feb. 2002;2(1):71-9. [pmid: 11888441].
18 Weiner JP, Tucker AM, Collins AM, et al. The development of a risk-adjusted capitation payment system: the Maryland Medicaid model. The Journal of ambulatory care management. Oct. 1998;21(4):29-52. [pmid: 10387436].
19 Bethell CD, Read D, Stein RE, Blumberg SJ, Wells N, Newacheck PW. Identifying children with special health care needs: development and evaluation of a short screening instrument. Ambul Pediatr. Jan–Feb. 2002;2(1):38-48. [pmid: 11888437].
20 Stein RE, Silver EJ, Bauman LJ. Shortening the questionnaire for identifying children with chronic conditions: what is the consequence?. Pediatrics. Apr. 2001;107(4):E61. [pmid: 11134435].
21 Stein RE, Westbrook LE, Bauman LJ. The Questionnaire for Identifying Children with Chronic Conditions: a measure based on a noncategorical approach. Pediatrics. Apr. 1997;99(4):513-21. [pmid: 9093290].
22 Iezzoni LI, Greenberg MS. Capturing and classifying functional status information in administrative databases. Health care financing review. Spring. 2003;24(3):61-76. [pmid: 12894635].
23 Leonardi M, Bickenbach J, Ustun TB, Kostanjsek N, Chatterji S. The definition of disability: what is in a name?. Lancet. Oct 7. 2006;368(9543):1219-21. [pmid: 17027711].
24 Perrin JM, Thyen U. Chronic illness. In: Levine MD, Carey WB, Crocker AC, editors. Developmental-Behavioral Pediatrics. 3 ed. Philadelphia: WB Saunders; 1999. p. 335–45.
25 McDonald KM, Sundaram V, Bravata DM. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies; In Press.
26 Ziring PR, Brazdziunas D, Cooley WC, et al. American Academy of Pediatrics. Committee on Children With Disabilities. Care coordination: integrating health and related systems of care for children with special health care needs. Pediatrics. Oct. 1999;104(4 Pt 1):978-81. [pmid: 10506246].
27 Pierce PM, Freedman SA. The REACH Project: an innovative health delivery model for medically dependent children. Child Health Care. Fall. 1983;12(2):86-9. [pmid: 10264195].
28 Fields AI, Coble DH, Pollack MM, Kaufman J. Outcome of home care for technology-dependent children: success of an independent, community-based case management model. Pediatric pulmonology. 1991;11(4):310-7. [pmid: 1758755].
29 US Department of Health and Human Services, Health Resources and Services Administration. Healthy People: 2010. Objective 16–22. Washington, DC: Department of Health and Human Services; 1999.
30 American Academy of Pediatrics. Standards of Child Health Care. Elk Grove, Ill: American Academy of Pediatrics; 1976.
31 American Academy of Pediatrics. The medical home. Pediatrics. Nov. 1992;90(5):774. [pmid: 1408554].
32 American Academy of Pediatrics. The medical home. Pediatrics. Jul. 2002;110(1 Pt 1):184-6. [pmid: 12093969].
33 American Academy of Pediatrics. The National Center of Medical Homes Initiative for Children with Special Needs. [Accessed; Available from: http://www.medicalhomeinfo.org/
34 Cooley WC, McAllister JW. Building medical homes: improvement strategies in primary care for children with special health care needs. Pediatrics. May. 2004;113(5 Suppl):1499-506. [pmid: 15121918].
35 American Academy of Pediatrics. Care coordination in the medical home: integrating health and related systems of care for children with special health care needs. Pediatrics. Nov. 2005;116(5):1238-44. [pmid: 16264016].
36 Cooley WC, McAllister JW, Sherrieb K, Clark RE. The Medical Home Index: development and validation of a new practice-level measure of implementation of the Medical Home model. Ambul Pediatr. Jul–Aug. 2003;3(4):173-80. [pmid: 12882594].
37 Center for Medical Home Improvement. Medical Home: Improvement Kit. Lebanon, NH: Hood Center for Children and Families, Children's Hospital at Dartmouth Hitchcock Medical Center; 2001.
38 West S, King V, Lohr K. Systems to rate the strength of scientific evidence. Rockville, MD: Agency for Healthcare Research and Quality; 2002.
39 West S, King V, Lohr K. Systems to rate the strength of scientific evidence: Appendix F. Rockville, MD: Agency for Healthcare Research and Quality; 2002.
40 Criscione T, Walsh KK, Kastner TA. An evaluation of care coordination in controlling inpatient hospital utilization of people with developmental disabilities. Mental retardation. Dec. 1995;33(6):364-73. [pmid: 8569486].
41 Liptak GS, Burns CM, Davidson PW, McAnarney ER. Effects of providing comprehensive ambulatory services to children with chronic conditions. Archives of pediatrics & adolescent medicine. Oct. 1998;152(10):1003-8. [pmid: 9790611].
42 Perrin JM, Homer CJ, Berwick DM, Woolf AD, Freeman JL, Wennberg JE. Variations in rates of hospitalization of children in three urban communities. The New England journal of medicine. May 4. 1989;320(18):1183-7. [pmid: 2710191].
43 Palfrey JS, Sofis LA, Davidson EJ, Liu J, Freeman L, Ganz ML. The Pediatric Alliance for Coordinated Care: evaluation of a medical home model. Pediatrics. May. 2004;113(5 Suppl):1507-16. [pmid: 15121919].
44 Farmer JE, Clark MJ, Sherman A, Marien WE, Selva TJ. Comprehensive primary care for children with special health care needs in rural areas. Pediatrics. Sep. 2005;116(3):649-56. [pmid: 16140704].
45 Chernoff RG, Ireys HT, DeVet KA, Kim YJ. A randomized, controlled trial of a community-based support program for families of children with chronic illness: pediatric outcomes. Archives of pediatrics & adolescent medicine. Jun. 2002;156(6):533-9. [pmid: 12038883].
46 Pless IB, Feeley N, Gottlieb L, Rowat K, Dougherty G, Willard B. A randomized trial of a nursing intervention to promote the adjustment of children with chronic physical disorders. Pediatrics. Jul. 1994;94(1):70-5. [pmid: 8008541].
47 Antonelli RC, Antonelli DM. Providing a medical home: the cost of care coordination services in a community-based, general pediatric practice. Pediatrics. May. 2004;113(5 Suppl):1522-8. [pmid: 15121921].
48 Jeffrey AE, Newacheck PW. Role of insurance for children with special health care needs: a synthesis of the evidence. Pediatrics. Oct. 2006;118(4):e1027-38. [pmid: 16966391].
49 Galbraith AA, Wong ST, Kim SE, Newacheck PW. Out-of-pocket financial burden for low-income families with children: socioeconomic disparities and effects of insurance. Health services research. Dec. 2005;40(6 Pt 1):1722-36. [pmid: 16336545]. [pmcid: 1361224].
50 van Dyck PC, Kogan MD, McPherson MG, Weissman GR, Newacheck PW. Prevalence and characteristics of children with special health care needs. Archives of pediatrics & adolescent medicine. Sep. 2004;158(9):884-90. [pmid: 15351754].
51 Kaye N. Medicaid managed care: Looking forward, looking back. Portland, ME: National Academy for State Health Policy; 2005.
52 Backus LI, Bindman AB. Low-income Californians' experiences with health insurance and managed care. Journal of health care for the poor and underserved. Nov. 2001;12(4):446-60. [pmid: 11688195].
53 Claxton G, Feder J, Shactman D, Altman S. Public policy issues in nonprofit conversions: an overview. Health affairs (Project Hope). Mar–Apr. 1997;16(2):9-28. [pmid: 9086646].
54 Rosenbaum S, Wise PH. Crossing the Medicaid-private insurance divide: the case of EPSDT. Health affairs (Project Hope). Mar–Apr. 2007;26(2):382-93. [pmid: 17339664].
55 Bergman DA, Homer CJ. Managed care and the quality of children's health services. The Future of children / Center for the Future of Children, the David and Lucile Packard Foundation. 1998 Summer–Fall;8(2):60–75.
56 Newacheck PW, Stein RE, Walker DK, Gortmaker SL, Kuhlthau K, Perrin JM. Monitoring and evaluating managed care for children with chronic illnesses and disabilities. Pediatrics. Nov. 1996;98(5):952-8. [pmid: 8909492].
57 Perrin JM, Kuhlthau K, Walker DK, Stein RE, Newacheck PW, Gortmaker SL. Monitoring health care for children with chronic conditions in a managed care environment. Maternal and child health journal. Mar. 1997;1(1):15-23. [pmid: 10728222].
58 RWJF. Chronic Care Initiatives in HMOs. Princeton, NJ: R.W.J. Foundation; 1992.
59 Berman S. The brave new bipartisan world of health care reform: how will low-income families with children with special health care needs fare?. Pediatrics. Aug. 2004;114(2):489-90. [pmid: 15286234].
60 Hohlen MM, Manheim LM, Fleming GV, et al. Access to office-based physicians under capitation reimbursement and Medicaid case management. Findings from the Children's Medicaid Program. Medical care. Jan. 1990;28(1):59-68. [pmid: 2404168].
61 Reis J. Medicaid maternal and child health care: prepaid plans vs. private fee-for-service. Research in nursing & health. Jun. 1990;13(3):163-71. [pmid: 2188303].
62 Alessandrini EA, Shaw KN, Bilker WB, Perry KA, Baker MD, Schwarz DF. Effects of Medicaid managed care on health care use: infant emergency department and ambulatory services. Pediatrics. Jul. 2001;108(1):103-10. [pmid: 11433061].
63 Baker LC, Afendulis C. Medicaid managed care and health care for children. Health services research. Oct. 2005;40(5 Pt 1):1466-88. [pmid: 16174143]. [pmcid: 1361210].
64 Hughes DC, Newacheck PW, Stoddard JJ, Halfon N. Medicaid managed care: can it work for children?. Pediatrics. Apr. 1995;95(4):591-4. [pmid: 7646653].
65 Wang EC, Choe MC, Meara JG, Koempel JA. Inequality of access to surgical specialty health care: why children with government-funded insurance have less access than those with private insurance in Southern California. Pediatrics. Nov. 2004;114(5):e584-90. [pmid: 15342825].
66 Kastner TA, Walsh KK, Criscione T. Overview and implications of Medicaid managed care for people with developmental disabilities. Mental retardation. Aug. 1997;35(4):257-69. [pmid: 9270234].
67 Currie J, Fahr J. Medicaid managed care: Effects on children's Medicaid coverage and utilization. Cambridge, MA: National Bureau of Economic Research; 2002.
68 LewinGroup. Medicaid managed care cost savings - A synthesis of fourteen studies. Falls Church, VA: America's Health Insurance Plans; 2004.
69 Berman S, Rannie M, Moore L, Elias E, Dryer LJ, Jones MD Jr. Utilization and costs for children who have special health care needs and are enrolled in a hospital-based comprehensive primary care clinic. Pediatrics. Jun. 2005;115(6):e637-42. [pmid: 15930189].
70 Mele NC, Flowers JS. Medicaid managed care and children with special health care needs: a case study analysis of demonstration waivers in three states. Journal of pediatric nursing. Apr. 2000;15(2):63-72. [pmid: 10808621].
71 Berman S, Armon C, Todd J. Impact of a decline in Colorado Medicaid managed care enrollment on access and quality of preventive primary care services. Pediatrics. Dec. 2005;116(6):1474-9. [pmid: 16322173].
72 Kaye N, Curtis D, Booth M. Certain Children with Special Health Care Needs: An Assessment of State Activities and Their Relationship to HCFA's Interim Criteria. Washington, DC: National Academy for State Health Policy; June 2000.
73 Mauldon J, Leibowitz A, Buchanan JL, Damberg C, McGuigan KA. Rationing or rationalizing children's medical care: comparison of a Medicaid HMO with fee-for-service care. American journal of public health. Jun. 1994;84(6):899-904. [pmid: 8203683]. [pmcid: 1614958].
74 Lieu TA, Finkelstein JA, Lozano P, et al. Cultural competence policies and other predictors of asthma care quality for Medicaid-insured children. Pediatrics. Jul. 2004;114(1):e102-10. [pmid: 15231981].
75 Shatin D, Levin R, Ireys HT, Haller V. Health care utilization by children with chronic illnesses: a comparison of medicaid and employer-insured managed care. Pediatrics. Oct. 1998;102(4):E44. [pmid: 9651412].
76 Chan B, Vanderburg N. Medicaid TEFRA option in Minnesota: implications for patient rights. Health care financing review. Fall. 1999;21(1):65-78. [pmid: 11481736].
77 Finkelstein JA, Barton MB, Donahue JG, Algatt-Bergstrom P, Markson LE, Platt R. Comparing asthma care for Medicaid and non-Medicaid children in a health maintenance organization. Archives of pediatrics & adolescent medicine. Jun. 2000;154(6):563-8. [pmid: 10850502].
78 Mitchell JB, Khatutsky G, Swigonski NL. Impact of the Oregon Health Plan on children with special health care needs. Pediatrics. Apr. 2001;107(4):736-43. [pmid: 11335752].
79 Mitchell JM, Gaskin DJ. Do children receiving Supplemental Security Income who are enrolled in Medicaid fare better under a fee-for-service or comprehensive capitation model?. Pediatrics. Jul. 2004;114(1):196-204. [pmid: 15231928].
80 Valet RS, Kutny DF, Hickson GB, Cooper WO. Family reports of care denials for children enrolled in TennCare. Pediatrics. Jul. 2004;114(1):e37-42. [pmid: 15231971].
81 Mitchell JM, Gaskin DJ. Factors affecting plan choice and unmet need among supplemental security income eligible children with disabilities. Health services research. Oct. 2005;40(5 Pt 1):1379-99. [pmid: 16174139]. [pmcid: 1361203].
82 Gadomski A, Jenkins P, Nichols M. Impact of a Medicaid primary care provider and preventive care on pediatric hospitalization. Pediatrics. Mar. 1998;101(3):E1. [pmid: 9417143].
83 Fox HB, McManus MA, Almeida RA. Managed care's impact on Medicaid financing for early intervention services. Health care financing review. Fall. 1998;20(1):59-72. [pmid: 10387426].
84 Cooper WO, Hickson GB, Gray CL, Ray WA. Changes in continuity of enrollment among high-risk children following implementation of TennCare. Archives of pediatrics & adolescent medicine. Nov. 1999;153(11):1145-9. [pmid: 10555715].
85 Grossman LK, Rich LN, Michelson S, Hagerty G. Managed care of children with special health care needs: the ABC Program. Clin Pediatr (Phila). Mar. 1999;38(3):153-60. [pmid: 10349080].
86 Roberto PN, Mitchell JM, Gaskin DJ. Plan choice and changes in access to care over time for SSI-eligible children with disabilities. Inquiry. Summer. 2005;42(2):145-59. [pmid: 16196312].
87 Millar JS, McCauley D, Hays C, Winston T, Mitchell L. Consumer Assessment of Health Plans Survey (CAHPS) results for Oklahoma managed care Medicaid, 1997, 1998, and 1999. J Okla State Med Assoc. Mar. 2000;93(3):109-17. [pmid: 10734703].
88 American Board of Pediatrics. Residency Review and Redesign in Pediatrics. [Accessed: December 16, 2006]; Available from: http://innovationlabs.com/r3p_public/
89 Shenkman E, Wu SS, Nackashi J, Sherman J. Managed care organizational characteristics and health care use among children with special health care needs. Health services research. Dec. 2003;38(6 Pt 1):1599-624. [pmid: 14727790]. [pmcid: 1360966].