# Summary and Recommendations

Despite the importance of care coordination for children with special health care needs, there is a relative paucity of evaluative evidence to guide its development and implementation. This observation is not directed at challenging the contention that care coordination is helpful to children with special health care needs and their families. The experience of countless families and providers caring for children with complex medical needs and the face validity of the goals of care coordination provide sufficient justification for maintaining care coordination's central role in shaping both child health practice and policy.

Rather, the primary challenge generated by this critical review of the relevant literature is whether current approaches to care coordination for CSHCN can substantially improve the quality of care for these children under current practice structures and policies. Framed somewhat differently, the current knowledge base seems inadequate to identify which care coordination strategies are most likely to be useful in any given practice setting.

The following sections summarize the central considerations informing this general assessment. They represent the primary findings of this review, interpreted and organized to help define the outstanding analytic issues concerning care coordination for CSHCN and recommendations for further research.

## Analytic Approach and Definitions

This technical review documents that the variety of analytic strategies that have been employed in evaluating care coordination for CSHCN not only reflects diverse practice and policy settings but also a remarkable analytic creativity in addressing this issue with relatively limited available resources. In addition, definitional issues continue to make the comparison of published studies difficult and more importantly, have helped create a confusing context for the assessment of program characteristics and ultimate effects. The most important of these analytic and definitional issues are summarized below, with each followed by a corollary recommendation.

### Heterogeneity in Identifying CSHCN

Considerable progress has been made in providing useful methods for defining and identifying CSHCN. However, there remains considerable variation in analytic approaches and definitions in the available literature. In addition, there remains a gap between recommended definitions for CSHCN and datasets with sufficient information to utilize these definitions in large populations of children. This is of particular importance as administrative datasets become available for research, monitoring and evaluation. Also worthy of special note is the observation that when the generally recommended definition of CSHCN is used, the group so defined is highly heterogeneous. Indeed, illness severity and functional impact are inherently continuous variables but the definition is largely used to make categorical yes/no designations. It should not be surprising therefore, that different programs or policies may find alternative or more restrictive definitions better suited to meet their evaluative needs.

Recommendation: Generate Consensus on Definition Use. The literature regarding CSHCN definition has been characterized by a search for a “preeminent” or at least consistent definition. However, it might prove useful to reexamine the growing experience with the MCHB definition, not to reconsider its content but rather to develop more consistent methodologic strategies to enhance its programmatic and analytic utility. For example, a fuller embrace of the definition as a programmatic screener or survey instrument might be enhanced if it were accompanied by agreed-upon, standard sets of supplementary variables that would be of direct use for programs and researchers concerned with subsets of CSHCN or trends in the epidemiology within the broad CSHCN population.

### Parent and Clinician Roles in Coordinating Care

Although there are a variety of approaches to care coordination, ^25^ in the pediatric literature there are differences in how the respective roles of parents and clinicians are framed and emphasized. In general, the use of the medical home concept has largely emphasized the central role of the clinician, and particularly the pediatrician. Other care coordination strategies have focused on the coordinative capacities of the parent and the utility of programmatic supports that can strengthen this role. While it is clear that any constructive care coordination model for children must include both parents and clinicians, there remain important differences that should be recognized, if not addressed, in shaping care coordination strategies. For example, there is growing interest in expanding reimbursement to clinicians for coordinative activities. This, in turn, may involve a formalization of the clinician's responsibilities for care coordination which, in some instances, may conflict with some care models that elevate and support a primary parental role. Such considerations may also become increasingly important as the practice of pediatrics responds more fundamentally to the challenges of childhood chronic disease in the years to come. ^88^

Recommendation: Integrate More Fully Parental and Clinician Roles in Care Coordination for CSHCN. Purposeful efforts to integrate the conceptual approaches and the various constituencies together should be strengthened. Clearly, the different coordinative approaches need not be mutually exclusive and the respective roles of parents and clinicians should be expected to vary in different settings or even as a child grows and develops. However, this review of care coordination for CSHCN suggests that important differences in approach exist and that they are best identified and addressed as part of the larger effort to develop coherent and collaborative care coordination strategies for CSHCN.

## Assessing the Impact of Care Coordination Interventions for CSHCN

### Inadequate Evaluation of Care Coordination Strategies

The number and quality of studies evaluating different care coordination strategies for CSHCN do not provide a strong empirical base for reaching general conclusions or assessing specific programmatic components of care coordination strategies for CSHCN. This assessment is not intended to suggest inaction in developing care coordination initiatives for CSHCN but rather some critical caution in shaping such programs in different practice and policy settings.

Of particular note is the lack of rigorous study design in the reviewed evaluations. In part, this reflects the relatively poor resource base of these studies. However, it may also reflect inadequate disciplinary connections between those focused on the provision of care to CSHCN and those developing new methods to evaluate clinical programs and improve the quality of health care.

Recommendation: Expand the Evaluation of Care Coordination Programs for CSHCN. Support for high quality evaluations of coordination interventions is desperately needed, particularly regarding health outcomes and costs. This enhanced effort should include:

- Greater emphasis on identifying the specific aspects of coordination particularly relevant to CSHCN and clearly describing how the implemented interventions address these discrete components of coordination;
- Mechanisms to enhance disciplinary interaction between care coordination programs and quality improvement methodologists to generate more rigorous evaluative strategies.

Given the growing pressure for greater efficiencies in delivering health care services in general and for the chronically ill in particular, there would seem to be important opportunities to generate an expanded evaluative agenda.

### Evaluating Replications of Promising Care Coordination Programs

Only one of the reviewed care coordination programs represented a replication (albeit modified) of a prior care coordination model. ^45^ Although different programs components are likely to be more useful in different practice settings, there could be some benefit in supporting the critical replication or scaling up of successful coordination models. Of particular note are the approaches reflected in the Pediatric Alliance for Coordinated Care (PACC) developed by Palfrey and colleagues. ^44^ This program could serve as a useful starting point for such replication efforts since it represents perhaps the most relevant and best evaluated coordination approach for primary care practices.

Recommendation: Support for the implementation and continued evaluation of PACC and related models should be enhanced.

### Care Coordination and Practice Structure and Policy

One of the basic observations made in this review is that the implemented care coordination efforts varied considerably and were related to different structures of child health care delivery and practice. This point has been made by Shenkman and colleagues ^89^ and suggests that care coordination interventions will likely need to be adapted for different settings.

Recommendation: Link Care Coordination Program Development to Practice and Policy Reform. Given the dynamic nature of health care delivery in the United States, this relationship between care coordination components and practice structures also suggests that the findings of any evaluation of care coordination for CSHCN should be interpreted within its historical context. Careful consideration should be given as to the relevance of the evaluated experience to current practice and policy trends. Therefore, as practice structures undergo change, the challenges and opportunities for coordination programs will change as well. The concern is that longstanding child health practice patterns may be increasingly out of step with the evolving epidemiology of childhood conditions and the growing efficiency demands of health policy reform. ^9^ This may be particularly true in meeting the enhanced, and often time consuming needs of CSHCN. Accordingly, efforts to enhance care coordination for CSHCN should be informed by a close consideration of practice and policy requirements.

## Managed Care for CSHCN Enrolled in Medicaid

### Lack of Child-focused Metrics for Assessing the Performance of Managed Care Systems for Poor CSHCN

Of note, while the reviewed studies utilized a variety of outcome measures, none of these were focused on measuring health outcomes directly.

Recommendation: Develop Performance Measures of Direct Relevance to CSHCN. Despite progress in developing performance measures for a variety of mainly adult health conditions, there are no standard performance measures of any meaning for CSHCN being utilized to assess either the capacity or performance of health plans or practices.

### Inadequate Information on the Impact of Managed Care for CSHCN

The implementation of managed care programs for CSHCN enrolled in Medicaid is moving forward rapidly despite an extremely weak knowledge base regarding its ultimate impact on the health of enrolled children and costs.

Recommendation: Urgently Expand the Evaluation of Managed Care for CSHCN. There is a critical and immediate need to assess the impact, problems, and missed opportunities associated with managed care strategies for CSHCN enrolled in Medicaid and other public programs for poor children. Special attention should be paid to documenting relevant coordinative components of the implemented programs and particularly, their impact on the coordination of care. Great caution should be exercised, therefore, in making broad judgments regarding the problems or benefits associated with this approach.