# Summary of Quality Assessment Criteria*

Domains | Critical Elements
Study question | Clearly focused and appropriate question
Study population | Description of study populations
Comparability of subjects | - Specific inclusion/exclusion criteria applied to all groups; - Comparability of groups at baseline; - Study groups comparable to non-participants with regard to confounding factors^†^; - Use of concurrent controls; - Comparability of follow-up among groups at each assessment
Exposure or intervention | Clear definition and measurement of exposure or intervention
Outcomes | Clear definition and measurement of outcomes
Statistical procedures | Assessment of confounding factors^†^
Results | Measurement of magnitude of effect for outcomes (e.g., odds ratio (OR) or relative risk (RR))
Discussion | Conclusions supported by results, with biases and limitations taken into consideration
Project funding or sponsorship | Type and source of support for study

* SOURCE: West S, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report/Technology Assessment No. 47 (Prepared by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center under Contract No. 290-97-0011). AHRQ Publication No. 02-E016. Rockville, MD: Agency for Healthcare Research and Quality. April 2002.

† Confounding is the alteration of the effect of one risk factor by the presence of another. Age, gender and socioeconomic status often are confounding factors because children with different values of these may be at differential risk of problem or disease. Confounding can be controlled by restricting inclusion criteria, by matching groups on the confounding factor, or by including the confounding variable in statistical analyses.

†† Specific exposure and outcomes definitions help to address measurement bias, the systematic error that occurs when measurement methods are consistently different between groups in the study.