# References

1 Cuervo LG, Aronson JK. The road to health care: balancing benefits and harms of interventions is essential. BMJ. 2004;329(7456):1-2. [pmid: 15231586]. [pmcid: 443424].
2 Juni P, Nartey L, Reichenbach S, Sterchi R, Dieppe PA, Egger PM. Risk of cardiovascular events and rofecoxib: cumulative meta-analysis. Lancet. 2004;364(9450):2021-9. [pmid: 15582059].
3 Psaty BM, Furberg CD, Ray WA, Weiss NS. Potential for conflict of interest in the evaluation of suspected adverse drug reactions: use of cerivastatin and risk of rhabdomyolysis. JAMA. 2004;292(21):2622-31. [pmid: 15572720].
4 Whittington CJ, Kendall T, Fonagy P, Cottrell D, Cotgrove A, Boddington E. Selective serotonin reuptake inhibitors in childhood depression: systematic review of published versus unpublished data. Lancet. 2004;363(9418):1341-5. [pmid: 15110490].
5 Alamowitch S, Eliasziw M, Barnett HJM. The risk and benefit of endarterectomy in women with symptomatic internal carotid artery disease. Stroke. 2005;36(1):27-31. [pmid: 15569876].
6 Rothwell PM. External validity of randomised controlled trials: “To whom do the results of this trial apply?”. Lancet. 2005;365(9453):82-93. [pmid: 15639683].
7 Birkmeyer JD, Stukel TA, Siewers AE, Goodney PP, Wennberg DE, Lucas FL. Surgeon volume and operative mortality in the United States. N Engl J Med. 2003;349(22):2117-27. [pmid: 14645640].
8 Derry S, Loke YK, Aronson JK. Incomplete evidence: the inadequacy of databases in tracing published adverse drug reactions in clinical trials. BMC Medical Research Methodology Vol 1: BMC Medical Research Methodology; 2001:Available at: http://www.biomedcentral.com/1471-2288/1/7.
9 Edwards JE, McQuay HJ, Moore RA, Collins SL. Reporting of adverse effects in clinical trials should be improved: lessons from acute postoperative pain. J Pain Symptom Manage. 1999;18(6):427-37. [pmid: 10641469].
10 Ethgen M, Boutron I, Baron G, Giraudeau B, Sibilia J, Ravaud P. Reporting of harm in randomized, controlled trials of nonpharmacologic treatment for rheumatic disease. Ann Intern Med. 2005;143(1):20-25. [pmid: 15998751].
11 Loke YK, Derry S. Reporting of adverse drug reactions in randomised controlled trials—a systematic survey. BMC Clinical Pharmacology. Vol 1; 2001:Available at http://www.biomedcentral.com/1472-6904/1471/1473.
12 Ioannidis JPA, Lau J. Completeness of safety reporting in randomized trials. JAMA. 2001;285(4):437-43. [pmid: 11242428].
13 Ioannidis JPA, Evans SJW, Gotzsche PC, et al. Better reporting of harms in randomized trials: an extension of the consort statement. Ann Intern Med. 2004;141(10):781-8. [pmid: 15545678].
14 Loke Y, Price D, Herxheimer A. Including adverse effects in your review. Paper presented at Cochrane Colloquium: 2003; Barcelona.
15 Chou R, Helfand M. Challenges in systematic reviews that assess treatment harms. Ann Intern Med. 2005;142(12 Pt 2):1090-9. [pmid: 15968034].
16 Egger M, Juni P, Bartlett C, Holenstein F, Sterne J. How important are comprehensive literature searches and the assessment of trial quality and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7:1-76.
17 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
18 Moher D, Jones A, Cook DJ, et al. Does quality of randomised trials affect estimates of intervention efficacy reported in meta-analyses. Lancet. 1998;352:609-13. [pmid: 9746022].
19 Schulz KF, Chalmers I, Hayes RJ. Empirical evidence of bias: dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408. [pmid: 7823387].
20 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-6. [pmid: 10493205].
21 Horton R. Vioxx, the implosion of Merck, and aftershocks at the FDA. Lancet. 2004;364(9450):1995-6. [pmid: 15582041].
22 Meenan RT, Saha S, Chou R, et al. Effectiveness and cost-effectiveness of echocardiography and carotid imaging in the management of stroke. Rockville, MD: Agency for Healthcare Research and Quality; 2002.
23 Bond R, Rerkasem K, Rothwell PM. Systematic review of the risks of carotid endarterectomy in relation to the clinical indication for and timing of surgery. Stroke. 2003;34(9):2290-303. [pmid: 12920260].
24 Rothwell PM, Slattery J, Warlow CP. A systematic review of the risks of stroke and death due to endarterectomy for symptomatic carotid stenosis. Stroke. 1996;27(2):260-5. [pmid: 8571420].
25 Rothwell PM, Slattery J, Warlow CP. A systematic comparison of the risks of stroke and death due to carotid endarterectomy for symptomatic and asymptomatic stenosis. Stroke. 1996;27(2):266-9. [pmid: 8571421].
26 Benavente O, Moher D, Pham B. Carotid endarterectomy for asymptomatic carotid stenosis: a meta-analysis. BMJ. 1998;317:1477-80. [pmid: 9831572]. [pmcid: 28726].
27 Lee KP, Schotland M, Bacchetti P, Bero LA. Association of journal quality indicators with methodological quality of clinical research articles. JAMA. 2002;287(21):2805-8. [pmid: 12038918].
28 Garfield E. The history and meaning of the journal impact factor. JAMA. 2006;295(1):90-3. [pmid: 16391221].
29 Bond R, Rerkasem K, Rothwell PM. Routine or selective carotid artery shunting for carotid endarterectomy (and different methods of monitoring in selective shunting). Stroke. 2003;34(3):824-5. [pmid: 12624319].
30 Rerkasem K, Bond R, Rothwell PM. Local versus general anaesthesia for carotid endarterectomy. Cochrane Database Syst Rev 2004;2.
31 Pagano M, Gauvreau K. Principles of biostatistics. 2nd ed. Pacific Grove CA: Duxbury Press; 2000.
32 Akaike H. A new look at the statistical model identification. IEEE Transaction on Automatic Control. 1974;AC-19:716-23.
33 Hurvich CM, Tsai CL. Regression and time series model selection in small samples. Biometrika. 1989;76(2):297-307.
34 Schwarz G. Estimating the dimension of a model. Annals of Statistics. 1978;6(2):461-4.
35 Burnham KP, Anderson DR. Model selection and inference: a practical information-theoretic approach. New York: Springer; 1998.
36 Geba GP, Polis AB, Najarian DK, Dixon ME, Storms WW, Weaver AL. Onset of efficacy and patient assessment of clinical response in osteoarthritis (OA): comparison of rofecoxib to nabumetone. J Am Geriatr Soc. 2001;49:S126.
37 Truitt KE, Lee M, DeTora LM, Anderson M, Zhao Rahway PL. Results of a pivotal (phase iii) placebo and active comparator controlled efficacy trial of rofecoxib 12.5 and 25 mg in adult patients with rheumatoid arthritis (ra). Arthritis Rheum. 2001;44(S9):S369.
38 Bombardier C, Laine L, Reicin A, et al. Comparison of upper gastrointestinal toxicity of rofecoxib and naproxen in patients with rheumatoid arthritis. Vigor study group. N Engl J Med. 2000;343(21):1520-8. [pmid: 11087881].
39 Lisse JR, Perlman M, Johansson G, et al. Gastrointestinal tolerability and effectiveness of rofecoxib versus naproxen in the treatment of osteoarthritis: a randomized, controlled trial. Ann Intern Med. 2003;139(7):539-46. [pmid: 14530224].
40 Barnett HJM. Carotid endarterectomy. Lancet. 2004;363(9420):1486-7. [pmid: 15135590].
41 Benson K, Hartz AJ. A comparison of observational studies and randomized, controlled trials. N Engl J Med. 2000;342(25):1878-86. [pmid: 10861324].
42 Britton A, McKee M, Black N, McPherson K, Sanderson C, Bain C. Choosing between randomised and non-randomised studies: A systematic review. Health Technol Assess 1998;2(13).
43 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342(25):1887-92. [pmid: 10861325]. [pmcid: 1557642].
44 Ioannidis JPA, Haidich A-B, Pappa M, et al. Comparison of evidence of treatment effects in randomized and nonrandomized studies. JAMA. 2001;286(7):821-30. [pmid: 11497536].
45 Schneeweiss S, Avorn J. A review of uses of health care utilization databases for epidemiologic research on therapeutics. J Clin Epidemiol. 2005;58:323-37. [pmid: 15862718].
46 Huwiler-Muntener K, Juni P, Junker C, Egger M. Quality of reporting of randomized trials as a measure of methodologic quality. JAMA. 2002;287(21):2801-4. [pmid: 12038917].
47 Bent S, Padula A, Avins AL. Better ways to question patients about adverse medical events. A randomized, controlled trial. Ann Intern Med. 2006;144:257-61. [pmid: 16490911].
48 Rothwell PM, Mehta Z, Howard SC, Gutnikov SA, Warlow CP. From subgroups to individuals: general principles and the example of carotid endarterectomy. Lancet. 2005;365(9455):256-65. [pmid: 15652609].
49 Juni P, Witschi A, Bloch R, Egger M. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
50 Balk EM, Bonis PAL, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287:2973-82. [pmid: 12052127].
51 Finlayson EVA, Birkmeyer JD, Stukel TA, Siewers AE, Lucas FL, Wennberg DE. Adjusting surgical mortality rates for patient comorbidities: More harm than good?. Surgery. 2002;132(5):787-94. [pmid: 12464861].