# Acknowledgments

The authors would like to acknowledge Peter Juni, M.D., for providing data on rates of myocardial infarction in clinical trials of rofecoxib; David Atkins, M.D., M.P.H., and Gurvaneet Randhawa, M.D., M.P.H., at the Agency for Healthcare Research and Quality for reviewing and providing insightful comments for earlier versions of this manuscript; and Jayne Schablaske for administrative support with this manuscript.