# Results

## Characteristics of Studies of CEA for Symptomatic Stenosis

We included 111 studies of CEA for symptomatic stenosis. Nine were randomized trials. Of 102 observational studies, 16 were population-based (attempted to assess all patients undergoing CEA in a pre-defined population). Eight of the 111 studies were published in journals with a high (>7) Journal Impact Factor. Eighty-two studies were performed in North America and 23 in Europe. Ten had a single surgeon author, 53 had multiple surgeon authors, and 48 had at least one non-surgeon author. Many studies did not report cardiovascular risk factors. For example, the proportion of patients with diabetes, the most frequently reported co-morbidity, was reported in 57 percent of studies.

## Tests of Association

Three quality criteria were very highly (p<0.001) associated with one another (Table 2): criterion 4 (adverse events pre-defined), criterion 5 (ascertainment technique adequate described), and criterion 6 (non-biased ascertainment). Overall quality rating (good, fair, or poor) was highly associated (p<0.0001) with author category (single surgeon, multiple surgeons, or at least one non-surgeon), funding source (mostly government, not reported, or other), and high (>7) Journal Impact Factor.

Table 2 Tests of association (p values shown*) for discrete independent variables in studies of carotid endarterectomy for symptomatic stenosis

| Quality criterion 1: Non-biased selection (yes or no) | Quality criterion 2: Adequate description of population (yes or no) | Quality criterion 3: Low (<5%) loss to follow-up (yes or no) | Quality criterion 4: Adverse events pre-defined (yes or no) | Quality criterion 5: Ascertainment technique adequately described (yes or no) | Quality criterion 6: Non-biased ascertainment (yes or no) | Quality criterion 7: Adequate duration (>30 days) of follow-up (yes or no) | Quality criterion 8: Statistical analysis of confounders (yes or no) | Quality rating (poor, fair, or good) | Author category (single surgeon author, multiple surgeons, or at least one non-surgeon) | Setting (North America, Europe, or other) | Funding source (pharmaceutical, mostly government, other, or unclear) | Prospective study (yes or no) | Population-based study (yes or no) | Randomized controlled trial (yes or no) | High (>7) Journal Impact Factor (yes or no) | Adverse events discussed by severity (yes or no) | Discussion of hospital or surgical volume or experience (yes or no)
Quality criterion 1: Non-biased selection | — | 0.6146 | 0.5536 | 0.0015 | 0.0008 | 0.0031 | 0.1387 | 0.0024 | <.0001 | 0.0723 | 0.9582 | 0.0024 | 0.0011 | 0.2849 | 0.0250 | 0.0252 | 0.6173 | 0.0592
Quality criterion 2: Adequate description of population | 0.6146 | — | 1.000 | 0.2392 | 0.9580 | 0.4705 | 0.2358 | 0.8882 | 0.0128 | 0.1170 | 0.7687 | 0.2090 | 0.5774 | 0.7164 | 0.2651 | 0.0173 | 0.8906 | 0.7378
Quality criterion 3: Low (<5%) loss to follow-up | 0.5536 | 1.000 | — | 0.5584 | 1.00 | 1.00 | 0.5774 | 0.0518 | 0.4260 | 1.00 | 1.00 | 0.3762 | 0.5584 | 1.00 | 1.00 | 1.00 | 0.5984 | 1.0000
Quality criterion 4: Adverse events pre-specified and defined | 0.0015 | 0.2392 | 0.5584 | — | <.0001 | <.0001 | 0.0832 | 0.0342 | <.0001 | 0.0023 | 0.6042 | 0.0149 | 0.6669 | 0.0077 | 0.0868 | 0.0002 | 0.6602 | 0.0035
Quality criterion 5: Ascertainment technique adequately described | 0.0008 | 0.9580 | 1.00 | <.0001 | — | <.0001 | 0.0012 | 0.0085 | <.0001 | <.0001 | 0.3734 | <.0001 | 0.5769 | <.0001 | 0.0267 | 0.0012 | 0.2807 | 0.0009
Quality criterion 6: Non-biased ascertainment | 0.0031 | 0.4705 | 1.00 | <.0001 | <.0001 | — | 0.0092 | 0.0273 | <.0001 | <.0001 | 0.7551 | <.0001 | 0.1525 | 0.0004 | 0.0022 | <.0001 | 1.00 | <.0001
Quality criterion 7: Statistical analysis of confounders | 0.0024 | 0.8882 | 0.0518 | 0.0342 | 0.0085 | 0.0273 | 0.2116 | — | 0.0001 | 0.0236 | 0.0358 | 0.1087 | 0.9061 | 0.0239 | 0.7277 | 0.7078 | 0.0974 | 0.0135
Quality criterion 8: Adequate duration (>30 days) of follow-up | 0.1387 | 0.2358 | 0.5774 | 0.0832 | 0.0012 | 0.0092 | — | 0.2116 | <.0001 | 0.1202 | 0.4790 | 0.003 | 0.0498 | 0.5554 | 0.0050 | 0.0114 | 0.8342 | 0.9684
Quality rating (poor, fair, or good) | <.0001 | 0.0128 | 0.4260 | <.0001 | <.0001 | <.0001 | <.0001 | <.0001 | — | <.0001 | 0.7060 | <.0001 | 0.0413 | 0.0006 | 0.0501 | <.0001 | 0.3064 | 0.0026

* p values reported for Fisher's exact test when there were less than 5 events in 1 or more cells; otherwise p values for chi-square tests

Bold values indicate associations between quality criteria in final 4-criteria quality rating instrument

## Univariate Analyses

For five of the eight individual quality items (non-biased selection, low loss to follow-up, adverse events pre-specified and defined, ascertainment technique adequately described, and non-biased and accurate ascertainment of adverse events), meeting the criterion was significantly (p<0.05) associated with differences in rates of stroke or death (Table 3). Criteria that were not associated with significant differences in estimates of stroke or death were criterion 2 (adequate description of population), criterion 7 (statistical analysis of confounders), and criterion 8 (adequate duration of follow-up).

Table 3 Univariate analyses of rates of stroke or death associated with carotid endarterectomy for symptomatic stenosis—discrete variables

Independent variable | Study category | Number of studies | Pooled rate of stroke or death (95% confidence interval) in univariate analyses | p value for difference in complication rates
Quality criterion 1: Non-biased selection | 1: adequate | 70 | 5.1% (4.4% to 5.8%) | p=0.0101
| 0: inadequate | 41 | 3.7% (2.9% to 4.5%)
Quality criterion 2: Adequate description of population | 1: adequate | 67 | 4.6% (3.9% to 5.3%) | p=0.9024
| 0: inadequate | 44 | 4.5% (3.7% to 5.4%)
Quality criterion 3: Low loss to follow-up, and patients lost to follow-up analyzed for adverse events | 1: adequate | 108 | 4.6% (4.1% to 5.2%) | p=0.0187
| 0: inadequate | 3 | 2.2% (0.3% to 4.2%)
Quality criterion 4: Adverse events pre-specified and defined | 1: adequate | 43 | 5.9% (4.9% to 6.8%) | p=0.0006
| 0: inadequate | 68 | 3.8% (3.2% to 4.4%)
Quality criterion 5: Ascertainment technique adequately described | 1: adequate | 35 | 5.7% (4.6% to 6.8%) | p=0.0082
| 0: inadequate | 76 | 4.0% (3.4% to 4.6%)
Quality criterion 6: Non-biased and accurate ascertainment of adverse events | 1: adequate | 32 | 5.7% (4.6% to 6.9%) | p=0.0136
| 0: inadequate | 79 | 4.1% (3.5% to 4.7%)
Quality criterion 7: Adequate statistical analysis of potential confounders | 1: adequate | 69 | 4.8% (4.1% to 5.5%) | p=0.1509
| 0: inadequate | 42 | 4.0% (3.2% to 4.9%)
Quality criterion 8: Adequate duration of follow-up | 1: adequate | 48 | 5.0% (4.1% to 5.9%) | p=0.1877
| 0: inadequate | 63 | 4.2% (3.5% to 4.9%)
Author category | Single author and surgeon | 10 | 2.8% (1.7% to 3.8%) | p=0.0327 (single versus multiple surgeons)
| | | | p<0.0001 (single surgeon versus non-surgeon)
| Multiple authors, all surgeons | 53 | 4.2% (3.5% to 4.9%) | P=0.0181 (multiple surgeons versus non-surgeon)
| At least one non-surgeon author | 48 | 5.6% (4.6% to 6.5%)
Setting | North America or Canada | 82 | 4.2% (3.6% to 4.8%) | p=0.0771 (North America versus Europe);
| | | | p=0.2395 (North America versus other)
| Europe | 23 | 5.7% (4.2% to 7.3%) | p=0.8560 (Europe versus other)
| Other, not reported or unclear, or international | 6 | 6.0% (3.1% to 9.0%)
Funding source | Mostly government | 14 | 5.3% (3.6% to 6.9%) | p=0.6221 (government versus other);
| | | | p=0.2479 (government versus not reported)
| Other | 15 | 5.9% (4.1% to 7.6%) | p=0.0810 (other versus not reported)
| Not reported or unclear | 82 | 4.2% (3.6% to 4.8%)
Prospective study | Yes | 31 | 5.2% (4.0% to 6.4%) | p=0.1851
| No | 80 | 4.3% (3.7% to 5.0%)
Population-based study | Yes | 16 | 6.3% (4.6% to 8.0%) | p=0.0259
| No | 95 | 4.3% (3.7% to 4.8%)
Randomized controlled trial | Yes | 9 | 7.4% (4.5% to 10.2%) | p=0.0444
| No | 102 | 4.4% (3.8% to 4.9%)
Published in high Journal Impact Factor journal | Journal Impact Factor >7 | 8 | 7.8% (4.8% to 10.8%) | p=0.0262
| Journal Impact Factor <=7 | 103 | 4.3% (3.8% to 4.9%)
Reports adverse events by severity | Yes | 58 | 4.8% (4.0% to 5.6%) | p=0.5281
| No | 51 | 4.4% (3.7% to 5.2%)
Analysis of hospital or surgeon volume or surgeon experience | Yes | 21 | 6.2% (4.7% to 7.7%) | p=0.0150
| No | 90 | 4.2% (3.6% to 4.7%)

Other variables associated with significantly higher rates of stroke or death were author category (studies with multiple authors and at least one non-surgeon having the highest rates), prospective study, population-based study, randomized controlled trial, high Journal Impact Factor, analysis of surgeon-related variables, and the patient population variables mean age and the proportion with coronary artery disease (Tables 3 and 4).

Table 4 Univariate analyses of rates of stroke or death in studies associated with carotid endarterectomy for symptomatic stenosis—continuous variables

Demographic or risk factor variable | Number of studies with available data | Odds ratio for risk of stroke or death per unit change in independent variable (95% confidence interval) | p value
Proportion of patients who smoke | 45 | 0.6137 (0.2087 to 1.8049) | 0.3667
Mean age of patients in study | 83 | 0.9671 (0.9356 to 0.9997) | 0.0479
Proportion of patients who are male | 87 | 1.0077 (0.9905 to 1.0252) | 0.3769
Proportion of patients who are white | 16 | 0.6741 (0.3626 to 1.2533) | 0.1953
Proportion of patients with diabetes | 63 | 0.7514 (0.1147 to 4.9244) | 0.7622
Proportion of patients with hypertension | 61 | 0.8433 (0.8433 to 3.1001) | 0.7943
Proportion of patients with coronary artery disease | 50 | 0.1645 (0.04864 to 0.5563) | 0.0045
Proportion of space devoted to discussion of adverse event assessment methods (cm of text/total text, excluding discussion section) | 111 | 1.0369 (1.0144 to 1.0598) | 0.0014
Proportion of space devoted to discussion of adverse event assessment results (cm of text/total text, excluding discussion section) | 111 | 1.0124 ( 0.9991 to 1.0258) | 0.0684

## Developing a Quality Rating Instrument

Using all eight quality criteria, reported rates of stroke or death were highest for studies rated good-quality (pooled rate 6.3 percent, 95% CI 4.6 percent to 8.0 percent), intermediate for fair-quality studies (5.3 percent, 95% CI 4.1 percent to 6.5 percent), and lowest for poor-quality studies (3.8 percent, 95% CI 3.2 percent to 4.4 percent); the differences were statistically significant for good versus poor (p=0.0076) and fair versus poor (p=0.0289), though not for good versus fair studies (p=0.3557).

To develop a more parsimonious quality rating instrument, we removed criterion 2 (adequate description of population), which was not associated with differential adverse event rates, and criteria 5 and 6, which were highly associated with (but not as predictive as) criterion 4 (adverse events pre-defined). After comparing all possible 4-item instruments using the remaining 5 criteria, we found that a quality rating instrument with criteria 1 (non-biased selection), 3 (low loss to follow-up), 4 (adverse events pre-defined), and 8 (adequate duration of follow-up) performed similarly to the 5-criteria instrument (Table 5). We also found that quality rating instruments using a single cutoff (adequate or inadequate) performed similarly to instruments using multiple cutoffs (good, fair, or poor). Using the 4-criteria instrument, studies rated “adequate” (score >=3 out of 4) had a significantly (p=0.003) higher pooled rate of stroke or death of 5.7 percent (95% CI 4.8 percent to 6.6 percent) compared to 3.7 percent (95% CI 3.1 percent to 4.3 percent) for studies rated “inadequate” (score <3). The summary quality rating also predicted rates of surgical complications better than any individual quality criterion.

Table 5 Analysis of different quality rating instruments on pooled rates of stroke or death associated with carotid endarterectomy for symptomatic stenosis

Quality rating instrument | Score | Number of studies | Pooled rate of stroke or death (95% confidence interval) in univariate analyses | Significance of differences in pooled complication rates | Goodness-of-fit
Quality instrument using 8 criteria and baseline cutoffs for good, fair, or poor | >6: good | 16 | 6.3% (4.6% to 8.0%) | p=0.0074 (good vs. poor), p=0.3530 (good vs. fair) | AIC=755.0, AICC=755.4, BIC=765.9
| >4 and <=6: fair | 27 | 5.3% (4.2% to 6.5%) | p=0.0290 (fair vs. poor)
| <=4: poor | 68 | 3.9% (3.3% to 4.5%)
Quality instrument using 8 criteria and 'best' cutoffs for good, fair, or poor | >5: good | 27 | 6.1% (4.8% to 7.4%) | p=0.0002 (good vs. poor), p=0.0187 (good vs. fair) | AIC=753.0, AICC=753.3, BIC=763.8
| >2 and <=5: fair | 64 | 4.4% (3.7% to 5.1%) | p=0.0207 (fair vs. poor)
| <=2: poor | 20 | 3.0% (2.1% to 4.0%)
Quality instrument using 7 criteria (excludes criterion 2, 'adequate description of population') and 'best' cutoffs for good, fair, or poor | >3: good | 54 | 5.6% (4.8% to 6.5%) | p<0.0001 (good vs. poor), p=0.0024 (good vs. fair) | AIC=747.8, AICC=748.2, BIC=758.7
| >1 and <=3: fair | 43 | 3.9% (3.2% to 4.6%) | p=0.0249 (fair vs. poor)
| <=1: poor | 14 | 2.5% (1.5% to 3.5%)
Quality instrument using 7 criteria (excludes criterion 2) and 'best' cutoffs for adequate or inadequate | >=4: adequate | 54 | 5.6% (4.8% to 6.5%) | p=0.0002 | AIC=750.0, AICC=750.3, BIC=758.2
| <4: inadequate | 57 | 3.6% (3.0% to 4.2%)
Quality instrument using 5 criteria (1, 3, 4, 7, and 8) and 'best' cutoffs for adequate or inadequate | >=4: adequate | 39 | 5.9% (4.8% to 6.9%) | p=0.0005 | AIC=752.8, AICC=753.1, BIC=761.0
| <4: inadequate | 72 | 3.9% (3.3% to 4.4%)
Quality instrument using 4 criteria (1, 3, 4, and 8) and 'best' cutoffs for adequate or inadequate | >=3: adequate | 50 | 5.7% (4.8% to 6.6%) | p=0.0003 | AIC=750.4, AICC=750.7, BIC=758.6
| <3: inadequate | 61 | 3.7% (3.1% to 4.3%)

For the four criteria instrument, a steady increase in the pooled complication rate was observed with increasing quality scores (scores of 1, 2, 3, and 4 associated with rates of 3.1 percent [95% CI 2.2 percent to 3.9 percent], 4.0 percent [95% CI 3.2 percent to 4.8 percent], 5.6 percent [4.4 percent to 6.7 percent], and 6.0 percent [4.5 percent to 7.4 percent], respectively). For instruments with more criteria, higher scores were associated with higher pooled complication rates until a threshold was reached at scores >=4 (Table 6).

Table 6 Pooled rate of stroke or death in studies of carotid endarterectomy for symptomatic stenosis according to number of quality criteria met

Quality score | Number of studies | Pooled rate of stroke or death (95% confidence interval)
7 criteria quality rating instrument (criteria 1, 3–8)
1 | 14 | 2.5% (1.5% to 3.5%)
2 | 21 | 4.1% (2.9% to 5.2%)
3 | 22 | 3.8% (2.8% to 4.7%)
4 | 21 | 5.3% (4.0% to 6.6%)
5 | 11 | 5.2% (3.9% to 6.6%)
6 | 10 | 5.3% (3.9% to 6.6%)
7 | 12 | 5.2% (3.8% to 6.6%)
5 criteria quality rating instrument (criteria 1, 3, 4, 7, 8)
1 | 15 | 2.6% (1.6% to 3.5%)
2 | 22 | 4.1% (3.0% to 5.3%)
3 | 35 | 4.2% (3.4% to 5.0%)
4 | 21 | 6.0% (4.6% to 7.4%)
5 | 18 | 6.0% (4.5% to 7.5%)
4 criteria quality rating instrument (criteria 1, 3, 4, 8)
1 | 23 | 3.1% (2.2% to 3.9%)
2 | 38 | 4.0% (3.2% to 4.8%)
3 | 30 | 5.6% (4.4% to 6.7%)
4 | 20 | 6.0% (4.5% to 7.4%)
3 criteria quality rating instrument (criteria 3, 4, 8)
1 | 45 | 3.4% (2.7% to 4.1%)
2 | 44 | 5.1% (4.2% to 6.0%)
3 | 22 | 5.9% (4.6% to 7.3%)

## Inter Rater Reliability

The overall quality rating (adequate or inadequate) using the four-criteria instrument was in agreement between two investigators for 19/20 of a random selection of studies (Kappa = 0.90).

## Multivariate Regression Analyses

A model with four individual quality criteria (1, 3, 4, and 8) performed similarly to a model using the composite four-criteria quality rating instrument that categorized studies as “adequate” or “inadequate” (AICC goodness-of-fit test 751.4 vs. 750.7). An “adequate” rating using the four-item instrument was an independent predictor of the reported adverse event rate after adjustment for North American setting (associated with lower complication rates), randomized controlled trial or population-based study design (each associated with higher complication rates), and the proportion of total text devoted to reporting adverse event results (higher proportion associated with higher complication rates) (Table 7). The four-criteria instrument performed similarly as a binary (adequate versus inadequate) or continuous (quality score 0–4) variable (AICC goodness of fit statistic 738.1 versus 738.6).

Table 7 Final multivariate model for rates of stroke or death in studies of carotid endarterectomy for symptomatic stenosis

Model | Independent variables initially entered into model | Independent variables in final model | Effect size (ln odds ratio) | p value | Goodness of fit statistics for model
Multivariate model using 4 criteria quality rating instrument | study rated ‘adequate’ (score >=3) | study rated ‘adequate’ (score >=3) | 0.3038 | p=0.0130 | AIC=737.1, AICC=738.1, BIC=756.0
| setting: North America | setting: North America | -0.4011 | p=0.0034
| setting: Europe
| randomized controlled trial | randomized controlled trial | 0.5361 | p=0.0140
| population-based study | population-based study | 0.4192 | p=0.0058
| proportion of text devoted to reporting adverse event results (continuous variable) | proportion of text devoted to reporting adverse event results (continuous variable) | 0.01505 | p=0.0167
| proportion of text devoted to reporting adverse event methods (continuous variable)
| prospective study
| Journal Impact Factor
| adverse events reported by severity
| surgical factors discussed (hospital or surgeon volume or experience)
| funding source not reported
| funding source governmental

AIC=Akaike's Information Criterion

AICC=corrected Akaike's Information Criterion

BIC=Schwarz-Bayesian Information Criterion

Adding high (>7) Journal Impact Factor or the variable “single surgeon author” to the multivariate model did not improve the model. No other variables were significant in multivariate models, though incomplete reporting in the primary studies limited analysis of demographic factors and comorbidities.

## Subgroup Analyses

An “adequate” quality rating (using the four-criteria instrument) was associated with higher reported complication rates across most clinical subgroups of patients, including patients with transient ischemic attacks (5.3 percent vs. 3.6 percent, p=0.0783), patients undergoing early (<3 to 6 weeks after symptoms) CEA (9.7 percent vs. 3.1 percent, p=0.0053), asymptomatic patients (reported separately from patients with symptoms) (3.2 percent vs. 1.4 percent, p=0.0021), and stroke patients (6.8 percent vs. 5.9 percent, p=0.3681). In multivariate analyses limited to the studies that reported mean age or proportion of patients with coronary artery disease, an “adequate” quality rating remained significant when controlling for those factors (Table 8). An “adequate” rating also predicted higher complication rates in univariate analyses of population-based observational studies (7.1 percent vs. 4.4 percent, p=0.0424) and non-population based observational studies (5.0 percent vs. 3.4 percent, p=0.0071), as well as in a multivariate model using data from all observational studies (excluding randomized trials).

Table 8 Multivariate models for rates of stroke or death in subgroups of studies of carotid endarterectomy for symptomatic stenosis

Model | Number of studies | Independent variables in final model | Effect size (in odds ratio) | p value
Multivariate model limited to studies reporting mean age | 83 | study rated ‘adequate’ (score >=3) | 0.4151 | p=0.0022
| | setting: North America | -0.3708 | p=0.0137
| | randomized controlled trial | 0.4568 | p=0.0562
| | population-based study | 0.3195 | p=0.0685
| | proportion of text devoted to reporting adverse event results (continuous variable) | 0.01444 | p=0.00776
| | mean age in years (continuous variable) | -0.02681 | p=0.1004
Multivariate model limited to studies reporting proportion of patients with coronary artery disease | 50 | study rated ‘adequate’ (score >=3) | 0.3395 | p=0.0135
| | setting: North America | -0.3618 | p=0.0258
| | randomized controlled trial | dropped from model (p>0.10)
| | population-based study | dropped from model (p>0.10)
| | proportion of text devoted to reporting adverse event results (continuous variable) | 0.01441 | p=0.0278
| | proportion of patients with coronary artery disease (continuous variable) | -0.01380 | p=0.0182

## Studies of CEA for Asymptomatic Stenosis

We included 18 studies of CEA for asymptomatic stenosis. Six were randomized trials, 15 were set in North American, and none were population-based studies. Rates of stroke and death were low in these studies, ranging from 0 percent to 4.6 percent.

None of the eight quality criteria (Table 9), quality rating instruments, or other clinical or study-design related variables were associated with significant differences in rates of stroke or death. Using the final four-criteria instrument developed based on the analyses of studies of CEA for symptomatic stenosis, rates of stroke or death were 2.4 percent and 2.5 percent in studies rated adequate and inadequate, respectively. In fact, little correlation was observed between quality scores and complication rates. For example, 7seven studies that only met one or two of the eight quality criteria reported complication rates ranging from 1.4 percent to 4.6 percent. Two studies that met seven or eight of the quality criteria reported complication rates of 1.3 percent and 3.0 percent.

Table 9 Univariate analyses of association between quality criteria and rates of stroke or death in studies of carotid endarterectomy for asymptomatic stenosis

Independent variable | Score | Number of studies | Pooled rate of stroke or death (95% confidence interval) | p value for difference in complication rates
Quality criterion 1: Non-biased selection | 1: adequate | 10 | 2.4% (1.8% to 3.1%) | 0.9763
| 0: inadequate | 8 | 2.4% (1.4% to 3.5%)
Quality criterion 2: Adequate description of population | 1: adequate | 13 | 2.4% (1.8% to 3.0%) | 0.7304
| 0: inadequate | 5 | 2.6% (1.2% to 4.1%)
Quality criterion 3: Low loss to follow-up and patients lost to follow-up analyzed for adverse events | 1: adequate | 18 | 2.4% (1.8% to 3.0%) | —
| 0: inadequate | 0 | —
Quality criterion 4: Adverse events pre-specified and defined | 1: adequate | 6 | 2.2% (1.4% to 3.0%) | 0.3551
| 0: inadequate | 12 | 2.7% (1.8% to 3.6%)
Quality criterion 5: Ascertainment technique adequately described | 1: adequate | 6 | 2.6% (1.8% to 3.4%) | 0.4132
| 0: inadequate | 12 | 2.2% (1.4% to 3.0%)
Quality criterion 6: Non-biased and accurate ascertainment of adverse events | 1: adequate | 6 | 2.6% (1.8% to 3.4%) | 0.4132
| 0: inadequate | 12 | 2.2% (1.4% to 3.0%)
Quality criterion 7: Adequate statistical analysis of potential confounders | 1: adequate | 5 | 2.4% (1.7% to 3.2%) | 0.9710
| 0: inadequate | 13 | 2.4% (1.6% to 3.3%)
Quality criterion 8: Adequate duration of follow-up | 1: adequate | 7 | 2.4% (1.7% to 3.2%) | 0.9463
| 0: inadequate | 11 | 2.4% (1.6% to 3.2%)

Because no variables were significant in univariate analyses, we did not attempt multivariate regression analyses.

## Studies of Rofecoxib

We included 16 randomized controlled trials of rofecoxib in patients with arthritis. Two studies published only as abstracts were excluded. ^36,^ ^37^ Two trials were published in journals with high (>7) Journal Impact Factor, four were published since 2001, and two were written by authors from a single department and institution. Pharmaceutical companies funded all of the trials.

In univariate analyses of the eight quality criteria, only criteria 6 (blinded external endpoint committee; pooled OR 3.69 versus 0.68, p<0.0001) and 7 (adequate statistical analysis of confounders; pooled OR 4.99 vs. 1.39, p=0.0164) were significantly associated with a higher risk for myocardial infarction (Table 10). Studies published in high Journal Impact Factor journals were the same as the studies that met criterion 7. Presence of an external endpoint committee blinded to treatment allocation was a stronger predictor of differences in risk for myocardial infarction when its presence was assessed using published or unpublished data than when relying only on published information (pooled OR 3.83 vs. 1.37, p=0.0468). Blinded assessment of complications (defined as assessor not aware of treatment allocation, but not necessarily a review committee independent from the study) was not associated with a significantly lower risk of myocardial infarction (pooled OR 1.68 vs. 3.94, p=0.2134).

Table 10 Univariate analyses of risk for myocardial infarction in randomized controlled trials of rofecoxib

Independent variable | Score | Number of studies | Pooled odds ratio for myocardial infarction, rofecoxib versus control | p value for difference in odds ratios
Quality criterion 1: Non-biased selection | 1: adequate | 6 | 2.19 (0.93 to 5.15) | 0.7212
| 0: inadequate | 10 | 1.80 (0.96 to 3.35)
Quality criterion 2: Adequate description of population | 1: adequate | 8 | 1.97 (1.02 to 3.78) | 0.9118
| 0: inadequate | 8 | 1.85 (0.83 to 4.13)
Quality criterion 3: Low loss to follow-up and patients lost to follow-up analyzed for adverse events | 1: adequate | 8 | 2.19 (1.16 to 4.12) | 0.5313
| 0: inadequate | 8 | 1.56 (0.69 to 3.51)
Quality criterion 4: Adverse events pre-specified and defined | 1: adequate | 4 | 2.64 (1.19 to 5.84) | 0.3417
| 0: inadequate | 12 | 1.59 (0.85 to 2.96)
Quality criterion 5: Ascertainment technique adequately described | 1: adequate | 10 | 2.10 (0.82 to 5.38) | 0.8282
| 0: inadequate | 6 | 1.85 (1.02 to 3.38)
Quality criterion 6: Non-biased and accurate ascertainment of adverse events | 1: adequate | 9 | 3.69 (2.61 to 5.20) | <0.0001
| 0: inadequate | 7 | 0.68 (0.42 to 1.09)
Quality criterion 7: Adequate statistical analysis of potential confounders | 1: adequate | 2 | 4.99 (2.28 to 10.93) | 0.0164
| 0: inadequate | 14 | 1.39 (0.86 to 2.25)
Quality criterion 8: Adequate duration of follow-up | 1: adequate | 7 | 1.69 (0.85 to 3.33) | 0.5874
| 0: inadequate | 9 | 2.24 (1.07 to 4.71)
Publication year | After 2001 | 4 | 2.71 (0.99 to 7.40) | 0.4563
| Before or during 2001 | 12 | 1.72 (0.97 to 3.06)
Setting | North America | 8 | 1.41 (0.63 to 3.15) | 0.4306
| Other | 6 | 2.22 (1.05 to 4.70)
Blinded outcomes assessment | Study had blinded assessment of complications. | 13 | 1.68 (0.99 to 2.83) | 0.2134
| Study not adequately blinded or unclear. | 3 | 3.94 (1.22 to 12.72)
External endpoint committee (published data only) | Study had an external endpoint committee according to published data. | 3 | 3.83 (1.81 to 8.07) | 0.0468
| Study does not meet above criteria or unclear. | 13 | 1.37 (0.80 to 2.36)
Published in high Journal Impact Factor journal | Journal Impact Factor >7 | 2 | 4.99 (2.28 to 10.93) | 0.0164
| Journal Impact Factor <=7 | 14 | 1.39 (0.86 to 2.25)
Author category | Multiple institutions or specialties | 14 | 2.11 (1.28 to 3.49) | 0.2260
| Single specialty and institution | 2 | 0.66 (0.12 to 3.72)
Reports adverse events by severity | Yes | 6 | 1.43 (0.63 to 3.27) | 0.3947
| No | 10 | 2.27 (1.23 to 4.21)

Using the four criteria quality rating instrument from the analyses of studies of CEA for symptomatic stenosis, quality rating (adequate or inadequate) was not associated with significant differences in odds ratios for myocardial infarction with rofecoxib relative to control interventions (2.59 versus 1.49, p=0.28) or with absolute rates of myocardial infarction on rofecoxib (0.34 percent versus 0.31 percent).

Analyses of this data set were limited by the small number of studies, and by the fact that two studies ^38,^ ^39^ with high odds ratios (4.98 and 5.00) for myocardial infarction contributed over half of the patients (13633 of 23725) in the included trials. Both of these trials also met seven out of the eight quality criteria.