# Methods

## Selection of Relevant Studies

Studies of CEA for symptomatic stenosis were identified from our earlier evidence review of diagnostic strategies for stroke ^22^ and augmented with studies from the reference lists of three other systematic reviews. ^23^ – ^25^ We included all randomized controlled trials, cohort studies, and surgical series reporting complication rates. We retrieved all studies of CEA for asymptomatic stenosis from the reference lists of two systematic reviews. ^25,^ ^26^ We also retrieved all of the randomized controlled trials of rofecoxib for arthritis included in a recent meta-analysis. ^2^ Abstracts were excluded because they provide insufficient information to adequately judge quality.

## Assessment of Study Quality

Study quality was assessed using eight criteria (Table 1). Each criterion was chosen on the basis of: (1) face validity as a marker of rigorous adverse event assessment, or (2) results from an earlier meta-analysis ^24^ of CEA suggesting predictability for adverse event rates. For instance, studies with independent assessment of complications (criterion 6) were associated with higher complication rates than studies in which the surgeon performing the procedure assessed complications. ^24^ Prospective or retrospective study design, on the other hand, was not included in our criteria list because it was not a significant predictor in the earlier meta-analysis. Examples of criteria that have not been empirically studied but had face validity include pre-defining of adverse events (criterion 4) and non-biased selection of patients for assessment of harms (criterion 1).

Table 1 Quality assessment tool for studies reporting adverse events

Criterion | Score
Quality criterion 1: Non-biased selection | 1: Study is a properly randomized controlled trial (according to Jadad criteria ^17^ ), or an observational study with a clear pre-defined inception cohort (that attempted to evaluate all patients in the inception cohort)
| 0: Study does not meet above criteria (e.g., convenience samples)
Quality criterion 2: Adequate description of population | 1: Study reports 2 or more demographic characteristics, presenting symptoms/syndrome and at least 1 important risk factor for complications
| 0: Study does not meet above criteria
Quality criterion 3: Low loss to follow-up | 1: Study reports number lost to follow-up, and the overall number lost to follow-up is low (threshold set at 5% for studies of carotid endarterectomy and 10% for studies of rofecoxib)
| 0: Study does not meet above criteria
Quality criterion 4: Adverse events pre-specified and defined | 1: Study reports explicit definitions for major complications that allow for reproducible ascertainment (what adverse events were being investigated and what constituted an event)
| 0: Study does not meet above criteria
Quality criterion 5: Ascertainment technique adequately described | 1: Study reports methods used to ascertain complications, including who ascertained, timing, and methods used
| 0: Study does not meet above criteria
Quality criterion 6: Non-biased ascertainment of adverse events | 1: Independent or masked assessment or complications (for studies of carotid endarterectomy, someone other than the surgeon who performed the procedure; for studies of rofecoxib, presence of an external endpoint committee blinded to treatment allocation)
| 0: Study does not meet above criteria
Quality criterion 7: Adequate statistical analysis of potential confounders | 1: Study examines 1 or more relevant confounders/risk factors (in addition to the comparison group in controlled studies), using acceptable statistical techniques such as stratification or adjustment
| 0: Study does not meet above criteria
Quality criterion 8: Adequate duration of follow-up | 1: Study reports duration of follow-up and duration of follow-up adequate to identify expected adverse events (threshold set at 30 days for studies of carotid endarterectomy and 6 months for studies of rofecoxib)
| 0: Study does not meet above criteria
Total quality score=sum of scores (0–8) | >6: Good
| 4–6: Fair
| <4: Poor

Adapted from Meenan et al. Effectiveness and Cost-Effectiveness of Echocardiography and Carotid Imaging in the Management of Stroke. Evidence Report/Technology Assessment Number 49. (Prepared by Oregon Health & Science University Evidence-based Practice Center under Contract No. 290-97-0018.) AHRQ Publication No. 02-E022. Rockville, MD: Agency for Healthcare Research and Quality. July 2002.

Studies were scored either 0 (inadequate) or 1 (adequate) for each criterion. Studies that did not report enough information to accurately assess a criterion were rated inadequate.

Several criteria deserve comment regarding their application. “Non-biased selection” (criterion 1) was judged adequate for randomized controlled trials if they were properly randomized according to the widely-used Jadad definition. ^17^ For observational studies, non-biased selection was judged adequate if the study defined an inception cohort and attempted to evaluate all patients meeting the definition. Examples of studies that would not meet this criterion are studies that evaluated convenience samples or studies in which an inception cohort was not clearly defined. “Adverse events pre-specified” (criterion 4) was judged adequate if the study reported the adverse events being investigated and how an “event” was defined.

Exact application of several criteria varied according to the intervention being studied. Specifically, we defined “adequate duration of follow-up” (criterion 8) as at least 30 days for studies of CEA and at least 6 months for studies of rofecoxib, and “low loss to follow-up” (criterion 3) as <5 percent for studies of CEA and <10 percent for studies of rofecoxib. For studies of CEA, “non-biased ascertainment” (criterion 6) was defined as ascertainment performed by someone other than the surgeon who did the procedure. For trials of rofecoxib, we defined “non-biased ascertainment” as assessment by a blinded, external endpoint committee. ^2^ For “adequate statistical analysis of potential confounders” (criterion 7), studies of CEA had to assess at least one confounder to meet the criterion. Trials of rofecoxib had to analyze at least one confounder in addition to the treatment group (rofecoxib versus control).

## Data Abstraction

Two investigators (R.C. and S.C.) independently applied the quality criteria and abstracted data for all studies. When quality assessments differed, consensus was reached before assigning final ratings. All quality assessments were made before complication rates were abstracted from each study.

We also abstracted the proportion of patients with cardiovascular comorbidities, study-level demographic characteristics (gender, race, and mean age), year of publication, funding source, setting, use of blinding (for the rofecoxib studies), and other study design features (such as randomized controlled trial or observational study, prospective or retrospective design, population-based or not population-based) in order to assess their impact on estimates of adverse events. We also abstracted variables that might be proxies for study quality such as author category (based on reported departmental and institutional affiliations), ^24^ whether the study reported severity of adverse events, the amount of text devoted to adverse events methods and reporting (recorded as the proportion of the total amount of text, excluding abstract and discussion), ^12^ and high (>7) Journal Impact Factor (based on 2003 data). Journal Impact Factor is a general measurement of journal quality ^27^ and is based on citation counts. ^28^ We selected a modest uniform threshold for classifying a journal as high Journal Impact Factor, though the interpretation of a specific value can vary depending on the journal's target audience (for example, a general medical audience versus a subspecialty journal). Because most CEA studies either did not report volume of surgeries or surgeon experience, we simply rated studies according to whether they did or did not analyze any surgeon-related variable. Variables such as use of shunting or type of anesthesia were not analyzed because they were not associated with differential complication rates in previous studies. ^29,^ ^30^ For studies of rofecoxib, the authors of a recent meta-analysis provided published and unpublished data on rates of myocardial infarction. ^2^ Because that meta-analysis found that the dose of rofecoxib, the type of control (placebo, nonnaproxen nonsteroidal anti-inflammatories, or naproxen), and adequate allocation concealment were not associated with differences in risks for myocardial infarction, we did not analyze these variables.

## Data Analysis

Chi-square tests or Fisher's exact tests (when cell values were less than five) were used to evaluate associations between individual quality criteria and other independent variables for each data set. Standard tests for heterogeneity were performed for all meta-analyses, with p values <0.10 considered significant.

Univariate analyses were performed to determine the association between individual methodological and clinical variables and adverse event rates. For each data set, random effects meta-regression models (in which between-study variance is incorporated into the analysis) were used to examine the effects of quality criteria and other study design and clinical or demographic factors on rates of stroke or death (studies of CEA) or odds ratios (OR) for myocardial infarction (trials of rofecoxib). The OR was evaluated as the dependent variable for trials of rofecoxib because of low absolute event rates (mean 0.3 percent). Data analyses for the rofecoxib trials were similar to analyses performed in a recently published meta-analysis. ^2^ Specifically, trials of rofecoxib with no events in both the rofecoxib and control group were excluded; control groups were combined; for any trial in which there were no events in either the rofecoxib or control group the OR was calculated by adding 0.5 to all cells; ^31^ and for trials with extensions, appropriate weighting was performed to avoid duplicate counting of data.

We calculated an initial summary quality score by adding up the scores of the eight criteria and assigned an initial overall quality rating based on the following arbitrary cutoffs: good=>6, fair=4–6, poor=<4. The univariate analyses and tests of association were used to develop more parsimonious quality rating instruments by removing non-predictive quality criteria, or those that did not improve the performance of quality rating instruments. Quality rating instruments were analyzed using different cutoffs for good, fair, or poor (three categories); adequate or inadequate (two categories); and the raw quality score as predictors of adverse events.

Multivariate meta-regression models using individual quality rating criteria or summary quality rating instruments and other clinical or study design-related variables were compared for goodness-of-fit using Akaike's Information Criterion (AIC), ^32^ corrected AIC (AICC), ^33^ and the Schwarz-Bayesian Information Criterion (BIC). ^34^ A smaller value of these criteria indicates a better fit, with a difference of 3 to 7 indicating an important difference between models. ^35^ Variables initially entered into the multivariate models were chosen based on the univariate analyses. Additional model selection was performed using backwards elimination methods. Variables that were highly correlated with quality ratings according to tests of association were preferentially removed during the model selection process, but we assessed their effects by adding them back to the final models.

When possible, subgroup analyses were performed to better control for the effects of clinical factors on complications. Additional analyses were also performed to assess the association between the raw quality score and complication rates using the baseline quality rating instrument and more parsimonious quality rating instruments.

All analyses were performed with SAS 9.1 (SAS Institute Inc., Cary, NC, U.S.A.).