# References

1 Rothwell PM. External validity of randomised controlled trials: “to whom do the results of this trial apply?”. Lancet. 2005;365:82-93. [pmid: 15639683].
2 Godwin M, Ruhland L, Casson I, et al. Pragmatic controlled clinical trials in primary care: the struggle between external and internal validity. BMC Med Res Methodol. 2003;3:28. [pmid: 14690550]. [pmcid: 317298].
3 Benson J, Britten N. Patients' decisions about whether or not to take antihypertensive drugs: qualitative study. BMJ. 2002;325:873. [pmid: 12386041].
4 Redelmeier DA, Rozin P, Kahneman D. Understanding patients' decisions. Cognitive and emotional perspectives. JAMA. 1993;270:72-6. [pmid: 8510300].
5 Thomas KB. General practice consultations: is there any point in being positive?. Br Med J (Clin Res Ed). 1987;294:1200-2.
6 Di Blasi Z, Harkness E, Ernst E, et al. Influence of context effects on health outcomes: a systematic review. Lancet. 2001;357:757-62. [pmid: 11253970].
7 Mulrow CD. Rationale for systematic reviews. BMJ. 1994;309:597-9. [pmid: 8086953]. [pmcid: 2541393].
8 Brook RH, Lohr KN. Efficacy, effectiveness, variations, and quality. Boundary-crossing research. Med Care. 1985;23:710-22. [pmid: 3892183].
9 Hoagwood K, Hibbs E, Brent D, et al. Introduction to the special section: efficacy and effectiveness in studies of child and adolescent psychotherapy. J Consult Clin Psychol. 1995;63:683-7. [pmid: 7593860].
10 Schwartz D, Lellouch J. Explanatory and pragmatic attitudes in therapeutical trials. J Chronic Dis. 1967;20:637-48. [pmid: 4860352].
11 Califf RM, DeMets DL. Principles from clinical trials relevant to clinical practice: Part I. Circulation. 2002;106:1015-21. [pmid: 12186809].
12 Peto R, Collins R, Gray R. Large-scale randomized evidence: large, simple trials and overviews of trials. J Clin Epidemiol. 1995;48:23-40. [pmid: 7853045].
13 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
14 Centre for Reviews and Dissemination. Undertaking systematic reviews of research on effectiveness: CRD's guidance for those carrying out or commissioning reviews. CRD Report No. 2nd ed. York, UK: NHS Centre for Reviews and Dissemination; 2001.
15 Gross CP, Mallory R, Heiat A, et al. Reporting the recruitment process in clinical trials: who are these patients and how did they get there?. Ann Intern Med. 2002;137:10-6. [pmid: 12093240].
16 Spahn J. Clinical trial efficacy: what does it really tell you?. J Allergy Clin Immunol. 2003;112:S102-6. [pmid: 14586394].
17 Fleming TR, DeMets DL. Surrogate end points in clinical trials: are we being misled?. Ann Intern Med. 1996;125:605-13. [pmid: 8815760].
18 Coutts JA, Gibson NA, Paton JY. Measuring compliance with inhaled medication in asthma. Arch Dis Child. 1992;67:332-3. [pmid: 1575560]. [pmcid: 1793677].
19 Gibson NA, Ferguson AE, Aitchison TC, et al. Compliance with inhaled asthma medication in preschool children. Thorax. 1995;50:1274-9. [pmid: 8553301]. [pmcid: 1021351].
20 Kelloway JS, Wyatt RA, Adlis SA. Comparison of patients' compliance with prescribed oral and inhaled asthma medications. Arch Intern Med. 1994;154:1349-52. [pmid: 8002686].
21 Norman GR, Sloan JA, Wyrwich KW. Interpretation of changes in health-related quality of life: the remarkable universality of half a standard deviation. Med Care. 2003;41:582-92. [pmid: 12719681].
22 Hollis S, Campbell F. What is meant by intention to treat analysis? Survey of published randomised controlled trials. BMJ. 1999;319:670-4. [pmid: 10480822]. [pmcid: 28218].
23 West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evid Rep Technol Assess (Summ) 2002 Mar;(47):1–11.
24 Geldmacher DS, Provenzano G, McRae T, et al. Donepezil is associated with delayed nursing home placement in patients with Alzheimer's disease. J Am Geriatr Soc. 2003;51:937-44. [pmid: 12834513].
25 Mendelman PM, Cordova J, Cho I. Safety, efficacy and effectiveness of the influenza virus vaccine, trivalent, types A and B, live, cold-adapted (CAIV-T) in healthy children and healthy adults. Vaccine. 2001;19:2221-6. [pmid: 11257337].
26 Jerrell JM. Cost-effectiveness of risperidone, olanzapine, and conventional antipsychotic medications. Schizophr Bull. 2002;28:589-605. [pmid: 12795493].
27 Kroenke K, West SL, Swindle R, et al. Similar effectiveness of paroxetine, fluoxetine, and sertraline in primary care: a randomized trial. JAMA. 2001;286:2947-55. [pmid: 11743835].
28 Little P, Gould C, Williamson I, et al. Pragmatic randomised controlled trial of two prescribing strategies for childhood acute otitis media. BMJ. 2001;322:336-42. [pmid: 11159657]. [pmcid: 26576].
29 Kawai N, Ikematsu H, Iwaki N, et al. Factors influencing the effectiveness of oseltamivir and amantadine for the treatment of influenza: a multicenter study from Japan of the 2002-2003 influenza season. Clin Infect Dis. 2005;40:1309-16. [pmid: 15825034].
30 Robles NR, Martin-Agueda B, Lopez-Munoz F, et al. Effectiveness and safety of eprosartan on pulse pressure for the treatment of hypertensive patients. Int J Clin Pract. 2005;59:478-84. [pmid: 15853868].
31 Bridges CB, Thompson WW, Meltzer MI, et al. Effectiveness and cost-benefit of influenza vaccination of healthy working adults: a randomized controlled trial. JAMA. 2000;284:1655-63. [pmid: 11015795].
32 Conley RR, Mahmoud R. A randomized double-blind study of risperidone and olanzapine in the treatment of schizophrenia or schizoaffective disorder. Am J Psychiatry. 2001;158:765-74. [pmid: 11329400].
33 Farlow M, Gracon SI, Hershey LA, et al. A controlled trial of tacrine in Alzheimer's disease. The Tacrine Study Group. JAMA. 1992;268:2523-9. [pmid: 1404819].
34 Follath F, Cleland JG, Just H, et al. Efficacy and safety of intravenous levosimendan compared with dobutamine in severe low-output heart failure (the LIDO study): a randomised double-blind trial. Lancet. 2002;360:196-202. [pmid: 12133653].
35 Gane E, Saliba F, Valdecasas GJ, et al. Randomised trial of efficacy and safety of oral ganciclovir in the prevention of cytomegalovirus disease in liver-transplant recipients. The Oral Ganciclovir International Transplantation Study Group. Lancet. 1997;350:1729-33. [pmid: 9413463].
36 Klassen TP, Watters LK, Feldman ME, et al. The efficacy of nebulized budesonide in dexamethasone-treated outpatients with croup. Pediatrics. 1996;97:463-6. [pmid: 8632929].
37 Knapp MJ, Knopman DS, Solomon PR, et al. A 30-week randomized controlled trial of high-dose tacrine in patients with Alzheimer's disease. The Tacrine Study Group. JAMA. 1994;271:985-91. [pmid: 8139083].
38 Maskell NA, Davies CW, Nunn AJ, et al. U.K. Controlled trial of intrapleural streptokinase for pleural infection. N Engl J Med. 2005;352:865-74. [pmid: 15745977].
39 McFalls EO, Ward HB, Moritz TE, et al. Coronary-artery revascularization before elective major vascular surgery. N Engl J Med. 2004;351:2795-804. [pmid: 15625331].
40 Meltzer HY, Alphs L, Green AI, et al. Clozapine treatment for suicidality in schizophrenia: International Suicide Prevention Trial (InterSePT). Arch Gen Psychiatry. 2003;60:82-91. [pmid: 12511175].
41 Final report on the aspirin component of the ongoing Physicians' Health Study. Steering Committee of the Physicians' Health Study Research Group. N Engl J Med 1989;321:129–35.
42 Plint AC, Osmond MH, Klassen TP. The efficacy of nebulized racemic epinephrine in children with acute asthma: a randomized, double-blind trial. Acad Emerg Med. 2000;7:1097-103. [pmid: 11015240].
43 Purdon SE, Jones BD, Stip E, et al. Neuropsychological change in early phase schizophrenia during 12 months of treatment with olanzapine, risperidone, or haloperidol. The Canadian Collaborative Group for research in schizophrenia. Arch Gen Psychiatry. 2000;57:249-58. [pmid: 10711911].
44 Rosenheck R, Cramer J, Allan E, et al. Cost-effectiveness of clozapine in patients with high and low levels of hospital use. Department of Veterans Affairs Cooperative Study Group on Clozapine in Refractory Schizophrenia. Arch Gen Psychiatry. 1999;56:565-72. [pmid: 10359474].
45 Rosenheck R, Perlick D, Bingham S, et al. Effectiveness and cost of olanzapine and haloperidol in the treatment of schizophrenia: a randomized controlled trial. JAMA. 2003;290:2693-702. [pmid: 14645311].
46 Schmid C, Richer M, Bilenge CM, et al. Effectiveness of a 10-day Melarsoprol schedule for the treatment of late-stage human African Trypanosomiasis: confirmation from a multinational study (Impamel II). J Infect Dis. 2005;191:1922-31. [pmid: 15871127].
47 Stiell IG, Wells GA, Field B, et al. Advanced cardiac life support in out-of-hospital cardiac arrest. N Engl J Med. 2004;351:647-56. [pmid: 15306666].
48 Dennis MS, Lewis SC, Warlow C. Effect of timing and method of enteral tube feeding for dysphagic stroke patients (FOOD): a multicentre randomised controlled trial. Lancet. 2005;365:764-72. [pmid: 15733717].
49 Wassef AA, Winkler DE, Roache AL, et al. Lower effectiveness of divalproex versus valproic acid in a prospective, quasi-experimental clinical trial involving 9,260 psychiatric admissions. Am J Psychiatry. 2005;162:330-9. [pmid: 15677599].
50 Davis BR, Cutler JA, Gordon DJ, et al. Rationale and design for the Antihypertensive and Lipid Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). ALLHAT Research Group. Am J Hypertens. 1996;9:342-60. [pmid: 8722437].
51 Yusuf S, Mehta SR, Xie C, et al. Effects of reviparin, a low-molecular-weight heparin, on mortality, reinfarction, and strokes in patients with acute myocardial infarction presenting with ST-segment elevation. JAMA. 2005;293:427-35. [pmid: 15671427].
52 Effectiveness of intravenous thrombolytic treatment in acute myocardial infarction. Gruppo Italiano per lo Studio della Streptochinasi nell'Infarto Miocardico (GISSI). Lancet 1986;1:397–402
53 MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet 2002;360:7–22.
54 National Emphysema Treatment Trial Research Group. Patients at high risk of death after lung-volume-reduction surgery. N Engl J Med. 2001;345:1075-83. [pmid: 11596586].
55 Schein OD, Katz J, Bass EB, et al. The value of routine preoperative medical testing before cataract surgery. Study of Medical Testing for Cataract Surgery. N Engl J Med. 2000;342:168-75. [pmid: 10639542].
56 Rossouw JE, Anderson GL, Prentice RL, et al. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA. 2002;288:321-33. [pmid: 12117397].
57 Jenicek M, Hitchcock DL. Logic and critical thinking in medicine. Chicago: AMA Press; 2005.