# Acknowledgments

We would like to thankfully acknowledge the directors of the U.S. and Canadian Evidence-based Practice Centers who selected the sample studies and provided insightful comments to the study protocol.