# Discussion

Our objective was to identify drug effectiveness studies reliably based on seven proposed criteria. We focused on studies of medications because they are common, but many of the same principles can be applied to other types of interventions. Because we attribute greater value to effectiveness studies than to efficacy studies, the specificity of this process had to be high. That is, we wanted to ensure that efficacy studies are not falsely rated as effectiveness studies. Erring on the side of exclusions appeared to be better than erring on the side of inclusions, given that most analysts will give greater emphasis to inferences drawn from effectiveness studies than from efficacy trials. Thus, on the one hand, trials identified as effectiveness studies must reliably have great external validity. On the other hand, criteria must not be so stringent as to exclude a large proportion of effectiveness studies. We found a cut-off of six criteria, which produced a specificity of 0.83 and a sensitivity of 0.72, most suitable for this rationale.

Our results should be interpreted cautiously for several reasons. First, the sample size of articles was small, which produces limitations in terms of using diagnostic parameters to test construct validity. The estimate of specificity is based on six efficacy studies only and has a great degree of uncertainty, with a “true” estimate between 0.36 and 1.00. Second, no validated definition of “effectiveness study” exists, and, EPC directors' views on the matter differed greatly. Nonetheless, the different EPCs represent a broad, valid spectrum of the current thinking in evidence-based medicine about effectiveness studies. Third, we excluded observational studies and included only trials (although not limited to RCTs). We strongly believe that observational studies have an important role in determining the effectiveness of drug interventions, especially with respect to long-term health outcomes and rare but severe adverse events. However, we limited our eligibility criteria to trials because they (especially RCTs) can best establish causation and minimize bias. Other designs, such as observational studies, may better reflect “real world” settings but can mainly indicate associations and only to a lesser degree determine causal effects. ^57^ Completely ruling out confounding in observational studies is not possible.

The applicability of our criteria for standard use in systematic reviews remains to be seen. Depending on the topic, some criteria could be predefined as “effectiveness eligibility criteria” at the start of a systematic review. For example, for a systematic review on Alzheimer's medications minimum length of follow-up (e.g., 6 months), typical primary care settings (e.g., nursing homes, office-based settings), and relevant health outcomes (e.g., nursing home placements, activities of daily living) could be defined a priori and reduce inter-rater differences.

Overall, our proposed criteria provide a simple, valid tool to distinguish effectiveness from efficacy studies. When the generalizability of included studies is given greater emphasis, through inclusion of effectiveness trials, systematic reviews can be made more generally applicable. Clinicians can apply our criteria to determine the external validity of individual studies given their particular populations of interest.