# Results

The EPC directors identified 26 studies. Of these, six were intended to illustrate efficacy trials and 20, effectiveness studies. We excluded two studies from the latter group because they did not meet eligibility criteria: ^24,^ ^25^ one was an observational follow-up of three RCTs ^24^ and the other a pooled analysis of clinical trials. ^25^ Of the remaining 24 studies ( Table 2 , alphabetical by author), 22 were RCTs, three with an open-label design ^26^ – ^28^ ; the other two were a nonrandomized, controlled trial ^29^ and an uncontrolled trial. ^30^

Table 2 Overview of studies identified by the EPC directors

Author, Year | Title | Study design | Sample Size | Funding
Bridges et al. 2000 ^31^ | Effectiveness and cost-benefit of influenza vaccination of healthy working adults: a randomized controlled trial | RCT, double-blind, placebo controlled | 2,375 | National Center for Infectious Diseases, CDC
Conley et al. 2001 ^32^ | A randomized double-blind study of risperidone and olanzapine in the treatment of schizophrenia or schizoaffective disorder | RCT, double-blind, head-to-head | 377 | Janssen Research Foundation
Farlow et al. 1992 ^33^ | A controlled trial of tacrine in Alzheimer's disease | RCT, double-blind, placebo-controlled | 468 | Parke-Davis
Follath et al. 2002 ^34^ | Efficacy and safety of intravenous levosimendan compared with dobutamine in severe low-output heart failure (the LIDO study): a randomised double-blind trial | RCT, double-blind, head-to-head | 203 | Orion Pharma, Espoo, Finland
Gane et al. 1997 ^35^ | Randomised trial of efficacy and safety of oral ganciclovir in the prevention of cytomegalovirus disease in liver-transplant recipients | RCT, double-blind, placebo-controlled | 304 | Roche Global Development Palo Alto, CA
Geldmacher et al. 2003 ^24^ | Donepezil is associated with delayed nursing home placement in patients with Alzheimer's Disease | Observational follow-up of RCTs | 1,115 | Eisai, Inc. and Pfizer, Inc.
Jerrell et al. 2002 ^26^ | Cost-effectiveness of risperidone, olanzapine, and conventional antipsychotic medications | RCT, open-label, head-to-head | 108 | South Carolina Dept of Mental Health
Kawai et al. 2005 ^29^ | Factors influencing the effectiveness of oseltamivir and amantadine for the treatment of influenza: a multicenter study from Japan of the 2002-2003 influenza season | non-randomized, open-label trial | 2,163 | Not stated
Klassen et al. 1996 ^36^ | The efficacy of nebulized budesonide in dexamethasone-treated outpatients with croup | Randomized, double-blind, placebo-controlled | 50 | Ontario Ministry of Health grant
Knapp et al. 1994 ^37^ | A 30-week trial of high-dose tacrine in patients with Alzheimer's disease | RCT, double-blind, placebo- controlled | 653 | Parke-Davis
Kroenke et al. 2001 ^27^ | Similar effectiveness of paroxetine, fluoxetine, and sertraline in primary care: a randomized trial | RCT, open-label, head-to-head | 573 | Ely Lilli
Little et al. 2001 ^28^ | Pragmatic randomized controlled trial of two prescribing strategies for childhood acute otitis media | RCT, open-label, head-to-head | 315 | NHS Research & Development
Maskell et al. 2005 ^38^ | U.K. controlled trial of intrapleural streptokinase for pleural infection | RCT, double-blind, placebo-controlled | 427 | UK Medical Research Council
McFalls et al. 2004 ^39^ | Coronary-artery revascularization before elective major vascular surgery | RCT, open-label | 510 | Cooperative Studies Program, Dept. VA Office of R&D
Meltzer et al. 2003 ^40^ | Clozapine treatment for suicidality in schizophrenia | RCT, open-label, head-to-head | 980 | Novartis; William K. Warren Research Foundation; Donald Test Foundation
Mendelmann et al. 2001 ^25^ | Safety, efficacy and effectiveness of the influenza virus vaccine, trivalent, types A and B, live, cold-adapted (CAIV-T) in healthy children and adults | Pooled analysis of RCTs | 10,443 | Aviron, NIH
Physicians Health Study 1989 ^41^ | Final report on the aspirin component of the ongoing physicians' health study | RCT, double-blind, placebo-controlled | 22,071 | NIH
Plint et al. 2000 ^42^ | The efficacy of nebulized racemic epinephrine in children with acute asthma: a randomized, double-blind trial | RCT, double-blind, head-to-head | 121 | Children's Hospital of Eastern Ontario Research Institute Grant;
Purdon et al. 2000 ^43^ | Neuropsychological change in the early phase of schizophrenia during 12 months of treatment with olanzapine, risperidone, or haloperidol | RCT, double-blind, head-to-head | 65 | Eli Lilly
Robles et al. 2005 ^30^ | Effectiveness and safety of eprosartan on pulse pressure for the treatment of hypertensive patients | Uncontrolled, open-label trial | 566 | None listed
Rosenheck et al. 1999 ^44^ | Cost-effectiveness of clozapine in patients with high and low levels of hospital use | RCT, double-blind, head-to-head | 423 | Dept. of VA Health Services; Sandoz
Rosenheck et al. 2003 ^45^ | Effectiveness and cost of olanzapine and haloperidol in the treatment of schizophrenia | RCT, double-blind, head-to-head | 309 | Eli Lilly; VA Cooperative Studies Program
Schmid et al. 2005 ^46^ | Effectiveness of a 10-day melarsoprol schedule for the treatment of late-stage human African trypanosomiasis: confirmation from a multinational study (Impamel II) | Uncontrolled, open-label trial | 2,020 | Swiss Agency for Development and Cooperation
Stiell et al. 2004 ^47^ | Advanced cardiac life support in out-of-hospital cardiac arrest | Open-label, controlled trial | 5,638 | Ontario Ministry of Health and Long-term Care
The Food Trial 2005 ^48^ | Effect of timing and method of enteral tube feeding for dysphagic stroke patients (FOOD): a multicenter randomized controlled trial | RCT, open-label | 859 | Multiple government assoc. in the UK, Singapore, & New Zealand
| | | 321
Wassef et al. 2005 ^49^ | Lower effectiveness of divalproex versus valproic acid in a prospective, quasi-experimental clinical trial involving 9,260 psychiatric admissions | Quasi-experimental, controlled trial | 5,228 | Not stated

NIH: National Institute of Health

Table 3 indicates whether each study met (Y) or did not meet (N) each criterion and gives the quality grade (good, fair, or poor); studies thought to be efficacy trials are given first, then studies thought to be effectiveness trials, and both sets are ranked by quality grade. For example, Follath et al. (a good efficacy trial) met only three of the seven criteria; by contrast, Bridges et al. (a good effectiveness trial) met all seven.

Table 3 Results of applying effectiveness criteria to studies selected by the EPC directors

Study | Item 1: Populations in primary care setting | Item 2: Less stringent eligibility criteria | Item 3: Health outcomes QOL | Item 4: Long study durations, clinically relevant study modalities | Item 5: Assessment of adverse events | Item 6: Adequate sample size | Item 7: ITT analysis | Quality Rating
Studies submitted as efficacy studies
Conley et al. 2001 ^32^ | N | N | N | N | Y | Y | Y | Fair
Follath et al. 2002 ^34^ | N | N | N | Y | N | Y | Y | Good
Gane et al. 1997 ^35^ | Y | Y | Y | Y | Y | Y | Y | Fair
Klassen et al. 1996 ^36^ | N | N | N | N | N | N | N | Fair
Plint et al. 2000 ^42^ | N | N | N | Y | N | Y | N | Fair
Purdon et al. 2000 ^43^ | Y | Y | N | Y | Y | N | N | Poor*
Studies submitted as effectiveness studies
Bridges et al. 2000 ^31^ | Y | Y | Y | Y | Y | Y | Y | Good
Farlow et al. 1992 ^33^ | Y | N | N | N | Y | Y | N | Poor†
Jerrell et al. 2002 ^26^ | N | N | Y | Y | Y | Y | N | Poor*
Kawai et al. 2005 ^29^ | Y | Y | Y | Y | N | Y | N | Fair
Knapp et al. 1994 ^37^ | Y | Y | N | Y | Y | Y | Y | Poor †
Kroenke et al. 2001 ^27^ | Y | Y | Y | Y | Y | Y | Y | Fair
Little et al. 2001 ^28^ | Y | Y | Y | Y | Y | Y | Y | Fair
Maskell et al. 2005 ^38^ | Y | N | Y | Y | Y | Y | Y | Good
McFalls et al. 2004 ^39^ | N | Y | Y | Y | Y | Y | Y | Good
Meltzer et al. 2003 ^40^ | Y | Y | Y | Y | Y | Y | Y | Fair
Physicians Health Study 1989 ^41^ | Y | Y | Y | Y | Y | Y | Y | Good
Robles et al. 2005 ^30^ | Y | Y | N | N | Y | Y | N | Fair
Rosenheck et al. 1999 ^44^ | N | Y | Y | Y | Y | Y | Y | Poor†
Rosenheck et al. 2003 ^45^ | N | Y | Y | Y | Y | Y | Y | Fair
Schmid et al. 2005 ^46^ | Y | Y | Y | Y | Y | N | Y | Poor† ‡
Stiell et al. 2004 ^45^ | Y | Y | Y | Y | N | Y | Y | Fair
The Food Trial 2005 ^47^ | Y | Y | Y | Y | N | Y | Y | Fair
Wassef et al. 2005 ^49^ | N | Y | Y | Y | Y | Y | N | Fair

* High number of post-randomization exclusions

† High attrition

‡ Completers-only analysis

Table 4 summarizes the diagnostic parameters at different cut-off points. Using a cut-off point of seven criteria (i.e., a trial meets all criteria to consider it an effectiveness study), we identified five of the 18 suggested effectiveness studies. This yielded a sensitivity of 0.28 and a specificity of 0.83. Employing six criteria as a cut-off raised the number of identified effectiveness trials to 13 with a corresponding sensitivity of 0.72 and a specificity of 0.83. A cut-off of five criteria led to a sensitivity of 0.89 and a specificity of 0.67.

Table 4 Summary of diagnostic parameters for different cut-off points

Diagnostic Parameters | Estimate | 95% Confidence Interval
Cut off: 7 (all) criteria fulfilled
Sensitivity (%): | 0.28 | 0.10 to 0.53
Specificity (%): | 0.83 | 0.36 to 1.00
+ Likelihood ratio | 1.7 | 0.4 to 10.1
- Likelihood ratio | 0.9 | 0.6 to 1.7
Cut off: 6 criteria fulfilled
Sensitivity (%): | 0.72 | 0.46 to 0.90
Specificity (%): | 0.83 | 0.36 to 1.00
+ Likelihood ratio | 4.3 | 1.2 to 24.4
- Likelihood ratio | 0.3 | 0.1 to 0.8
Cut off: 5 criteria fulfilled
Sensitivity (%): | 0.89 | 0.65 to 0.99
Specificity (%): | 0.67 | 0.22 to 0.96
+ Likelihood ratio | 2.7 | 1.2 to 9.3
- Likelihood ratio | 0.2 | 0.0 to 0.6

Based on the rationale that we want to identify effectiveness studies reliably with minimal false positives (i.e., high specificity), a cut-off of six criteria produced the most desirable balance between sensitivity and specificity. At this point, the positive likelihood ratio was 4.3, the negative likelihood ratio 0.3. In other words, a true effectiveness study is 4.3 times more likely to be identified as such than an efficacy trial.

We did not reach a higher specificity because of one study that was nominated as an efficacy trial. ^35^ However, three reviewers independently classified this trial as an effectiveness study. This trial assessed the efficacy and safety of oral ganciclovir in preventing cytomegalovirus disease in liver-transplant recipients. The settings were multiple university clinics in Europe and the United States. In our view, liver transplantations will never be conducted in primary care facilities; tertiary care facilities participating in this trial, although highly specialized, will always be the setting of initial care for patients undergoing organ transplantations. Because all the other criteria were also fulfilled, we deemed this study to be an effectiveness trial. Removing this study from our calculations raises the positive likelihood ratio to 8.5 with a specificity of 0.92 and a sensitivity of 0.71.

The methodological quality of the studies was mixed. Of the 18 effectiveness studies, five (28 percent) received a “poor” quality rating. High attrition and a high number of post-randomization exclusion were the principal reasons for poor internal validity. Nevertheless, most of these studies still provide valuable information. For example, two trials assessing the effectiveness of tacrine in patients with Alzheimer's disease were rated “poor” because of high attrition (>50%). ^33,^ ^37^ However, the high attrition rate was attributable primarily to the hepatotoxicity of tacrine. Therefore, although the internal validity to determine the effectiveness of tacrine is compromised, these studies still provide valuable information about the risk-benefit ratio of tacrine. An efficacy study, with an active run-in period before randomization, might have concealed such findings.

In addition to the studies identified by the EPC directors we applied our criteria to seven trials that are frequently used as examples of effectiveness studies in the published literature. ^50^ – ^56^ Using a cut-off point of six criteria we identified all seven trials as effectiveness studies.