# Methods

Based on clinical and methodological considerations and the published literature, we selected seven domains of study design that, in our view, demonstrably influence the generalizability of trial results ( Table 1 ). We searched MEDLINE® to identify published literature on instruments to distinguish effectiveness from efficacy studies. We found various definitions of effectiveness studies ^8^ – ^12^ but no validated rating instruments. Additional searches on Web sites of the U.S. Agency for Healthcare Research and Quality (AHRQ), U.S. Centers for Disease Control and Prevention (CDC), Cochrane Collaboration, and the U.K. National Institute for Clinical Effectiveness Web sites did not yield any results.

Table 1 Proposed criteria to distinguish effectiveness from efficacy trials

Item 1 | Populations in primary care
Item 2 | Less stringent eligibility criteria
Item 3 | Health outcomes
Item 4 | Long study duration; clinically relevant treatment modalities
Item 5 | Assessment of adverse events
Item 6 | Adequate sample size to assess a minimally important difference from a patient perspective
Item 7 | Intention-to-treat analysis

Given the lack of a validated gold standard, we asked the directors of 12 Evidence-based Practice Centers (EPCs) in the United States and Canada to nominate six trials each. Four were to exemplify effectiveness studies and two, efficacy trials. The EPCs are programs that conduct systematic reviews for the AHRQ for a variety of audiences, including the CDC, U.S. National Institutes of Health, the U.S. Preventive Services Task Force (USPSTF), professional societies, and other health care groups. Any trial was eligible, regardless of design; observational studies or observational follow-ups of trials were ineligible. Our intent was to use the selected effectiveness and efficacy studies as if they had been identified by a gold standard method. The EPC directors possess many years of experience in systematic reviews, and we considered them the natural source of expertise for this effort. For masking purposes, we did not disclose our proposed criteria to EPC directors during their trial selection.

Once we had the nominated trials in hand, two independent raters applied our criteria to distinguish effectiveness from efficacy trials; they were blinded to which studies the EPC directors had identified as efficacy or effectiveness studies. Reviewers also assessed the internal validity (quality) of trials based on predefined criteria from the USPSTF (ratings: good-fair-poor) ^13^ and the National Health Service Centre for Reviews and Dissemination. ^14^

We viewed diagnostic test parameters (i.e., sensitivity, specificity, likelihood ratios) as an intuitive and appropriate way to test the construct validity of our criteria. We determined diagnostic parameters for different cut-off points (i.e., seven criteria fulfilled, six criteria fulfilled, and so on) to assess how well our criteria identified effectiveness studies. To ensure reliability, we applied our criteria to seven trials that are frequently referred to as effectiveness studies in the published literature. We did all statistical analyses with StatsDirect 2.3.8.

## Proposed Criteria

### 1. Populations in Primary Care

Efficacy studies are frequently conducted in large tertiary-care, referral settings, which tend to have more specialized clinicians and better technical equipment than primary care facilities. Subjects in such studies typically live in areas with ready access to such health centers and have accepted such referrals. They are often better educated and have better insurance coverage than the average primary care patient.

Primary care settings vary depending on health condition and available infrastructure. For people with most diseases, office-based locations, primary-care clinics, or community health centers are the initial setting for health care. Under specific circumstances, such as children or frail, elderly populations, schools or nursing homes may be the site of primary care.

For effectiveness trials, settings should reflect the initial care facilities available to a diverse population with the condition of interest. For persons with rare or severe diseases or those requiring high-risk interventions, such as organ transplantations, specialized secondary or tertiary care settings may provide initial care. Therefore, depending on the indication of interest, primary care settings may not always be an adequate criterion.

### 2. Less Stringent Eligibility Criteria

A common criticism of RCTs is that enrolled populations are highly selected and unrepresentative of the general population affected by the condition under consideration. Recruitment often employs stringent eligibility criteria to minimize adverse events and potential nonresponders. Some trials screen up to 68 people for each person enrolled. ^15^ Prerandomization run-in periods to exclude placebo-responders or poorly compliant patients additionally limit external validity.

For effectiveness trials, eligibility criteria must allow the source population to reflect the heterogeneity of external populations: the full spectrum of the human population, their co-morbidities, variable compliance rates, and use of other medications (or other therapies, such as psychotherapies, or complementary and alternative medications). Co-morbidities and other medications cannot be general exclusion criteria unless they contraindicate the use of the agent in ordinary practice.

Recruitment issues (e.g., volunteer bias, cultural barriers, language issues) may limit generalizability, perhaps severely for certain populations. For example, persons in minority ethnic groups are often underrepresented, and findings from trials among adults cannot be extrapolated to children. In North America, English language ability and literacy are prerequisites for participation in most trials, rendering immigrant groups ineligible for enrollment.

### 3. Health Outcomes

Clinical trials generally evaluate three types of outcome measures: subjective, objective, and health-related. ^16^ Efficacy studies, especially phase III clinical trials, commonly use objective or subjective outcomes (e.g., symptom scores, laboratory data, or time to disease recurrence) to determine intermediate (surrogate) outcomes. Assessments of health outcomes (e.g., functional capacity, quality of life, mortality) may be less commonly included as primary outcome measures. Short-term changes in symptom scores or laboratory data may provide valuable information regarding treatment mechanisms of improvement. Improvements in intermediate outcome measures, however, cannot always be reliably extrapolated to improvements in health outcomes. ^17^

Health outcomes, relevant to the condition of interest, should be the principal outcome measures in effectiveness studies. Intermediate outcomes are adequate only if empirical evidence verifies that the effect of the intervention on an intermediate endpoint predicts and fully captures the net effect on a health outcome. ^17^

### 4. Long Study Duration, Clinically Relevant Treatment Modalities

External validity is limited if study protocols do not reflect clinical practice. Efficacy trials (of pharmaceuticals) are required for approval purposes, and investigators design study durations and treatment modalities to prove an effect and ensure safety. Such trials may not last as long as therapy would in everyday practice. Additionally, they may rely on strict diagnostic criteria that are usually not employed in primary care settings.

In effectiveness trials, study durations should mimic a minimum length of treatment in a clinical setting to allow the assessment of health outcomes. Treatment modalities should reflect clinical relevance (e.g., no fixed-dose designs; equivalent dosages for head-to-head comparisons). Diagnosis should rely on diagnostic standards that practicing physicians use.

In efficacy trials, investigators need to ensure (or measure) compliance to determine whether an intervention works. In clinical settings, however, adherence to therapy is often low; ^18,^ ^19^ it may depend on dosage regimens, ^20^ side effects profiles, and demographic or socioeconomic circumstances of the patients. In effectiveness trials, therefore, investigators should define compliance as an outcome measure, because unpredictable or “poor” compliance can render an efficacious treatment ineffective. ^2^

### 5. Assessment of adverse events

Objective assessment of adverse events over an appropriate period of time is crucial to evaluate the balance of benefits and risks of any treatment. Reporting adverse events in RCTs is often limited; the methods of adverse events assessments are frequently poor. Rarely do investigators employ objective scales of adverse events (e.g., the World Health Organization scale of adverse events). Patient self-reporting often excludes “embarrassing” adverse events such as sexual side effects. To some extent, discontinuation rates and compliance, if assessed as outcomes, reflect adverse events.

Ideally, effectiveness studies use objective scales with predefined adverse events to determine adverse events rates. However, using an extensive objective adverse events scale is often not feasible in daily clinical practice because of time constraints and practical considerations. Therefore, adverse events assessments in effectiveness trials could be limited to critical issues based on experiences from prior trials.

### 6. Adequate Sample Size To Assess a Minimally Important Difference From a Patient Perspective

The power of a study to detect a statistically significant difference depends primarily on sample size. Large, simple trials with few levels of analysis provide the ideal study design to detect small but clinically significant treatment effects. ^12^ Small studies, specifically noninferiority drug trials may lack the statistical power to detect clinically significant differences between two treatments. Norman et al. propose one-half of a standard deviation as a good guideline to determine the effect size of a minimally important difference on health-related quality of life instruments from a patient's perspective. ^21^ In a normally distributed sample this equates to a sample size of n = 64 per arm for a two-tailed test, not considering any loss to follow up. This sample size calculation, however, cannot be applied to studies with dichotomous outcomes or skewed continuous data.

The sample size of an effectiveness trial should be sufficient to detect at least a minimally important difference on a health-related quality of life scale. Therefore, we propose a minimum starting sample size of n = 75 participants per treatment arm to factor in a possible attrition of 15 percent. For conditions where rare but significant outcomes such as mortality or hospitalizations are of main interest, sample sizes must be greater and based on adequate power calculations. For example, differences in the rates of mortality (e.g., antiplatelet drugs for acute myocardial infarction) or hospitalization (e.g., inhaled corticosteroids for chronic obstructive pulmonary disease) may be of greater interest than health-related quality of life scores.

### 7. Intention-to-treat (ITT) analysis

ITT analysis maintains treatment groups that are similar except for random variation. ^22^ Given sound randomization and allocation concealment, ITT distributes known and unknown confounders equally across treatment groups. To some extent ITT analysis takes the effects of lack of adherence and varying reasons for treatment discontinuations into consideration when estimating effect sizes. The primary goal of efficacy trials is to determine if a treatment works under ideal circumstances. Ideal circumstances, however, require minimization of factors that can alter a treatment effect. Therefore, statistical analyses in efficacy trials frequently exclude patients with protocol deviations. In clinical practice, however, factors such as compliance, adverse events, drug regimens, co-morbidities, concomitant treatments, or costs all can alter efficacy. A “completers only” analysis would not take these factors adequately into account.

## Internal Validity

Apart from designating a trial as an effectiveness or efficacy study, internal validity should be assessed; various rating scales and methods are available for such assessments. ^23^ Good or fair internal validity are prerequisites of external validity. To maintain internal validity, adequate randomization and allocation concealment are critical elements. Effectiveness trials often require cluster randomization to deal with contamination issues. ^2^

A triple-blinded design (investigators, patients, and outcomes assessors or data analysts, if different from investigators) is a very difficult design to implement in effectiveness studies; even a double-blinded design (investigators/assessors and patients) is often not possible. For certain outcomes, such as all-cause mortality, blinding is not necessary because subjectivity plays no role. For investigations of surgical interventions masking patients may be extraordinarily difficult for practical and ethical reasons; masking observers measuring outcomes may be more feasible. Insofar as masking is crucial to avoid measurement bias, however, even when a double-blinded design is not achievable, outcomes assessment or data analysis must be blinded whenever possible.