# References

1 Evidence-based Practice Centers. Overview. AHRQ Publication No. 03-P006, March 2003. Agency for Healthcare Research and Quality, Rockville, MD. Available at: http://www.ahrq.gov/clinic/epc/. Last accessed on March 15, 2005.
2 Martin, MG. Delivering project excellence with the SOW. Vienna, VA: Management Concepts; 2002.
3 Project Management Institute. A guide to the Project Management Body of Knowledge (PMBOK). Pennsylvania: Project Management Concepts; 2000.
4 Dettmer HW. Goldratt's Theory of Constraints: A systems approach to continuous improvement. Milwaukee: ASQ Quality Press; 1997.
5 Cleland DI, King WR. Management: a systems approach. New York: McGraw-Hill; 1972.
6 Kerzner H. Project management: a systems approach to planning, scheduling, and controlling. New York: John Wiley; 2001.
7 Loring R, Kerzner H. Proposal preparation and management handbook. New York: Van Nostrand Reinhold Publishers; 1982.
8 Stern PC, Fineberg HV. Understanding risk: informing decisions in a democratic society. Washington, DC: National Academy Press; 1996.
9 Walker DM, Walker T, Schmitz J. Doing business internationally: the guide to cross-cultural success. New York: McGraw Hill; 2002.
10 Cibinic J, Nash RC. Administration of government contracts. Washington, DC: George Washington University Press; 1995.
11 Cibinic J, Nash RC. Formation of government contracts. Washington, DC: George Washington University Press; 1998.
12 Keyes WN. Government contracts: under the Federal Acquisition Regulation. St. Paul, MN: Thompson/West; 2003.
13 Keyes W. Noel. Government contracts: in a nutshell. St. Paul, MN: Thompson/West; 1990.
14 Oppenheim, AN. Questionnaire design, interviewing and attitude measurement. London: Pinter Publishers; 1992.
15 Moser CA, Kalton G. Survey methods in social investigation. New York: Basic Books; 1972.
16 Bernard HR. Social research methods: qualitative and quantitative approaches. Thousand Oaks, CA: Sage Publications; 2000.
17 Banta HD, Andreasen PB. The political dimension in health care technology assessment programs. Int J Technol Assess Health Care. 1990;6(1):115-23. [pmid: 2361816].
18 Walshe K, Rundall TG. Evidence-based management: from theory to practice in health care. Milbank Q 2001;79(3):429–57, IV–V.
19 Lilford R, Jecock R, Shaw H, et al. Commissioning health services research: an iterative method. J Health Services Research Policy. Jul. 1999;4(3):164-7.
20 Frenk J. Balancing relevance and excellence: organizational responses to link research with decisionmaking. Soc Sci Med. Dec. 1992;35(11):1397-404. [pmid: 1462179].
21 Canadian Health Services Research Foundation. Conference Report from Can Health Serv Res Fdn Ann Invitational Workshop. March 2002. Productive Partnership. Available at: http://www.chsrf.ca/knowledge_transfer/pdf/2002_workshop_report_e.pdf. Last accessed: March 10, 2005.
22 Goering P, Butterill D, Jacobson N, et al. Linkage and exchange at the organizational level: a model of collaboration between research and policy. J Health Services Research Policy. Oct. 2003;8(Suppl 2):14-9.
23 Lomas J. Connection research and policy. ISUMA-Canadian Journal of Policy Research 2000; Vol 1(1),pp140–4.
24 Sorian R, Baugh T. Power of information: closing the gap between research and policy. When it comes to conveying complex information to busy policy-makers, a picture is truly worth a thousand words. Health Affairs. Mar–Apr. 2002;21(2):264-73.
25 Alberta Heritage Foundation for Medical Research. A study of the impact of 2000-01 HTA Products. Jan 2002. Available at: http://www.inahta.org/Reports.asp?name=Content12/Dokument/4+AHFMR+Impact.pdf. Last accessed: March 10, 2005.
26 Eagar K, Cromwell D, Owen A, et al. Health services research and development in practice: an Australian experience. J Health Services Research Policy. Oct. 2003;8(Suppl 2):7-13.
27 Canadian Health Services Research Foundation; Central West Planning Information Network; Centre for Health Economics and Policy Analysis; Health Evidence, Linkage and Application Network (HEALNet); Institute for Clinical Evaluative Sciences; Institute for Work and Health. Conference Report from Knowledge Transfer: Looking beyond Health. Toronto, October 26–27, 2002. Available at: http://www.chsrf.ca/knowledge_transfer/pdf/ktransfer_e.pdf. Last accessed: March 10, 2005.
28 Canadian Research Transfer Network; Health Resarch Transfer Network of Alberta. Conference Report from Knowledge Transfer: in Health Alberta, Oct 24–25, 2002. Available at: http://www.chsrf.ca/knowledge_transfer/pdf/2002_workshop_report_e.pdf. Last accessed: March 10, 2005.
29 Bartunek J, Trullen J, Bonet E, et al. Sharing and expanding academic and practitioner knowledge in health care. J Health Services Research Policy. Oct. 2003;8(Suppl 2):62-8.
30 Lavis JN, Robertson D, Woodside JM, et al. Knowledge transfer study group. How can research organizations more effectively transfer research knowledge to decisionmakers? Milbank Q 2003;81(2):221–48, 171–2.
31 Ross S, Lavis J, Rodriguez C, et al. Partnership experiences: involving decision-makers in the research process. J Health Services Research Policy. Oct. 2003;8(Suppl 2):26-34.
32 Ascher W. Forecasting: an appraisal for policy-makers and planners. Baltimore: The John Hopkins University Press; 1978.
33 Cole PS. How to write a statement of work. Vienna, VA: Management Concepts; June 2003.
34 Mather C, Costello A. An innovative approach to performance-based acquisition: Using a SOO. Acquisition solutions, Inc. May 1, 2001. Available at: http://www.acqsolinc.com/docs/adv0501.pdf. Last accessed: March 10, 2005.
35 Federal Acquisition Regulation, FAC 24, July 19, 2004. Available at: http://www.arnet.gov/far/. Last accessed: March 10, 2005.