# Step 4: Identify Promising Solutions for the Core Constraints to Develop the Future Reality Tree Based on the Theory of Constraints

## Solutions Methods

The objective here is to identify promising solutions/change strategies to address the root causes that lead to a report that is not used, and to depict a desired future through a Future Reality Tree. The Future Reality Tree is one of the five logic trees that TOC proposes. The UDE from the CRT (e.g. "Report is not used) is the desired effect (DE) of the Future Reality Tree (“Report is used”), and it results from one or more proposed injections (e.g. “establish on ongoing relationship between partner, EPC, and AHRQ starting early on”).

Note that, as described in the Introduction, we are particularly interested in strategies that can be articulated in the SOW while including approaches that need not be incorporated into a SOW document. These approaches however must be consistent with the concept of SOW and can function as clear principles guiding the EPC process.

The result of the Step 3, the CRT exercise, was the identification of the core constraint (partner does not know how to conceptualize and articulate needs, objectives, and specifications). Our interviews and literature search allowed us to explore possible change strategies and promising solutions to address this core constraint. In addition, at the 2004 annual EPC directors meeting we presented the CRT and solicited solutions (injections in TOC terminology). We listed all these solutions, chose the most promising ones from our discussions with the EPC directors (and from Steps 1 and 2), and developed a Future Reality Tree (Figure 3).

Figure 3. Future Reality Tree of the SOW process for EPCs

## Solutions Results

The interviews, literature search, and input from the directors' meeting identified several potential injections/change strategies:

- Establish a formally supported relationship between partners, researchers and the EPC early in the process.
- Involve a knowledge transfer expert. This expert will enable communication, reduce cultural tensions between researchers and partners, manage expectations, and guide the development of the SOW.
- Ensure frequent and ongoing communication, as well as the development of long-term partnerships between researchers and decisionmakers, in order to develop cultural sensitivity.
- Consider the current EPC SOW a “proposal SOW.” This rough SOW would be utilized during the competitive bidding situation, while a revised SOW is created with input from the EPC, AHRQ, and partners within the first 30 days after contract award.
- Provide funding specifically for the EPCs to perform preliminary research in order to estimate the time and budgetary resources required for the stated scope of work (e.g. based on volume of literature, nature of expected end product).
- Utilize a changes clause in the SOW; in more complex tasks include formal Scope Change Control.

The relation between the injections, and the root causes they could potentially attack are illustrated in the following table:

Solutions (injections) that can address root causes of EPC-SOW problems

Injection | Root causes that the injection can address
Establish an ongoing relationship between partners, EPC, and AHRQ early in the process | 1 Partner does not know how to conceptualize a SOW; 2 Specifications for a report are not initially sufficient
Involve a knowledge transfer expert | 1 Partner does not know how to conceptualize a SOW; 2 Specifications for a report are not initially sufficient
Concept of “proposal SOW” that is revised with EPC-input | 1 Partner does not know how to conceptualize a SOW; 2 Specifications for a report are not initially sufficient
Provide funding for EPCs to perform preliminary research | 1 Volume of anticipated work is under-estimated by the EPCs; 2 True cost and time requirement of the project are underestimated
Utilize a changes clause | 1 Specifications for a report change mid-stream; 2 Partners needs change late in the process; 3 Budget and timeline cannot be changed in response to changes in project specifications

With these concepts of UDEs, root causes, and injections that lead to converting a UDE to a DE, we constructed the Future Reality Tree for the EPC-SOW process (Figure 3).

- The two injections (establish an ongoing relationship between partners, EPC, and AHRQ early in the process, and utilize a changes clause) were deemed to be the most practical means to exert impact on the SOW process by addressing the core constraint, partner does not know how to conceptualize and articulate needs, objectives and specifications of the SOW.
- The injections (change strategies) lead to the ability of a partner to conceptualize and articulate needs, objectives and specifications of the SOW (the core constraint is addressed by the injection).
- This ultimately results in the production of a successful EPC report that meets partner needs and therefore will be used (opposite of the UDE, the DE).