# Step 2: Literature Review

## Literature Review Methods

MEDLINE® database searches were conducted in an iterative manner during April–July 2004 to retrieve articles related to technical contracting literature relating to formulating SOWs for the production of policy reports and similar intellectual products, as well as the policy literature related to the determinants of a successful policy analysis. Search terms included “statement of work,” “policy and research,” “translational research,” “research transfer,” and “dissemination and implementation.” No specific key words were required as inclusion criteria; a relatively small number of studies exist on the topic, so a “bottom-up” search strategy was required. Journal articles were retrieved from diverse fields of study: policy analysis, organizational behavior, project management, health services research, environmental research, and Federal documents. The reference lists of each article were reviewed in detail to find additional articles.

Two reviewers independently read each article in full text (n = 51 articles, including 4 Federal documents), evaluated the relevance of retrieved articles, and recorded the main findings of each study in a table. Reviewers slated each article in the table for “inclusion” or “exclusion” based on the article's relevance to the topic. Included articles described problems and solutions associated with interactions between researchers and decisionmakers (38/51 articles were included). The main problems identified in each article and their proposed solutions were recorded. A set of 11 key themes emerged early, and key themes were recorded.

Key themes were:

1 Timing of the technical report
2 Communication between researchers and decisionmakers
3 Aligning goals
4 Managing expectations
5 Defining role/responsibility
6 Understanding cultural differences between researchers and decisionmakers
7 Using a knowledge transfer expert
8 Defining key questions
9 Ensuring non-normativity
10 Creating a useful product
11 Addressing ethical, legal, or social implications (ELSI) of a research report

The few initial articles that had been reviewed before the key themes emerged were re-reviewed to specifically identify key themes. A third reviewer read all of the articles deemed relevant by the two primary reviewers and resolved any disagreements about the relevance of a given article.

In addition, to address the goal of understanding the technical aspects of developing an SOW, a standard text entitled Delivering Project Excellence with the Statement of Work by Michael G. Martin ^2^ was read by one reviewer, who provided the other two reviewers with a written summary. This book describes the development of a successful statement of work from a management perspective. Information gathered from this text provided a foundation for thinking about statements of work. Other books from project management, ^3^ – ^7^ risk analysis, ^8^ business, ^9^ government contracting, ^10^ – ^13^ and qualitative analysis, ^14^ – ^16^ were used for background information, and written summaries of the relevant information were shared with all reviewers.

In reviewing the literature, we concluded that the major themes were conceptually similar to those uncovered in the informant interview, although they were perhaps articulated a bit differently. Indeed, we were able to regroup the 11 themes above into the three areas covered by the informant interview: cultural/educational factors (the problem of two cultures—analysts and decisionmakers), strategic factors (establishing mechanisms for facilitating a seamless link between the analysis and the ultimate application), and resource factors (effectively addressing resource issues initially and over time). Thus, for simplicity of exposition, we focus here on specific insights proposed in the literature linked to each of the three themes.

## Literature Review Results

### Culture/Education Factors

The differences between researchers and decisionmakers are manifest in multiple fundamental ways, ranging from the way they choose to craft questions (as researchable bites vs. broader policy questions), ^17^ – ^19^ to their attitudes towards time, ^20^ to their perceptions of success. ^21^ The literature suggests that these differences are firmly rooted in professional culture. This polarization is described frequently in the literature in terms of researchers valuing “excellence,” while decisionmakers prize “relevance” most highly. ^20,^ ^22^ On the issue of attitudes towards time, researchers have been dubbed “chronophilic,” while decisionmakers are “chronophobic.” ^20^ Researchers are stimulated by key questions that may take years to answer, because answering compelling scientific questions is their life's work. Researchers are thus “chronophilic,” always seeking more time to answer questions in greater depth. Decisionmakers, in contrast, are “chronophobic,” chasing time against the next deadline. Decisionmakers have frequent, absolute deadlines; if a report is not available for a meeting at which a decision is made, it is useless.

Assuming that researchers and policymakers articulate key questions in researchable form, and bridge misunderstandings during project development, cultural differences may still sabotage the final product. Lomas points out that researchers and decisionmakers tend to connect more frequently at the end of a research project, when trying to generate a final product. ^23^

Different professional cultures generate different visions of the end product. Sorian and Baugh's survey of 292 State government decisionmakers revealed that aides to decisionmakers may read longer evidence reports, but decisionmakers often need shorter, simpler end products than researchers envision. ^24^ It has been suggested in that researchers should be prepared to do simple, quick evidence syntheses as well as detailed ones if that is what the partner truly needs. ^25^

The literature supports the notion of approaching cultural differences through active education and integration. Many studies advocated communication between researchers and decisionmakers as early as possible, even during the proposal stage. ^26^ In addition to formal efforts at educating each other in their languages, tools and values, one recommendation in the Canadian Health Services Research Foundation (CHSRF) conference report entitled Knowledge Transfer: Looking Beyond Health is that researchers should ask about the policy implications of the questions they are considering, if they are not explicitly told. ^27,^ ^28^ Many forms of interactive communication have been suggested to help break down cultural barriers: posting draft guidelines on a Web site for public comment, Internet discussion boards, and even “exchanges,” in which researchers and policymakers actually trade jobs for a period of time. ^29^

### Strategic Factors

In addition to concerns raised in the Step 1 interviews, the literature provided additional insight into strategic concerns. Eight of the 38 articles we reviewed stressed the importance of a “knowledge transfer expert.” Knowledge transfer experts are individuals who are trained to promote communication, reduce cultural tensions, guide the development of a conceptual framework, manage expectations, and otherwise bridge the gap that researchers and decisionmakers have neither time nor incentive to bridge. As a measure of what resources such work might require, a study of 265 applied research organizations in Canada revealed that on average, 14 percent of organizational budget went to knowledge transfer. ^30^

One strategic determinant of a successful technical report is clear definition of roles and responsibilities. As described by Ross et al., there are several roles that partners can play in the research process. ^31^ First, a partner can be a “formal supporter” (financial support only); second, a partner can be a “responsive audience;” third, a partner can be an “integral partner.” ^31^ Some studies suggest that role and responsibility definition is important because it encourages all parties to treat each other as equals. ^21^

A related issue is the importance of establishing the operational definition of non-normativity. Typically, EPC reports are intended to inform, not direct, policy. Sorian and Baugh's survey of 292 State government decisionmakers revealed that decisionmakers want to see potential implications of various decisions within evidence reports, but not researcher opinion. ^24^ The importance of the researcher avoiding the role of policymaker is further reinforced by a review of the topic of technical policy analysis by Asher. ^32^

### Resource Factors

The general management/contracting literature is largely focused on balancing work and costs, and is an area in which the SOW is noted to be of particular relevance. Two crucial resource issues are accounting for project costs when the true costs are not known until work begins, and adjusting funding to account for changes in project scope, as when new issues become apparent.

One issue raised in the literature is the critical importance of the due diligence phase. ^33,^ ^34^ The due diligence phase allows the contractor to understand the objectives, problems, and constraints of the requesting organization. It is customary to pay contractors during the due diligence phase.

A contracting concept relevant to the production of policy reports is that of the relational contract. Relational contracts are “service contracts in which the contract performance requirements are continually evolving and accurately specifying the requirements in advance will be difficult, if not impossible; the relationship if the government and contractor...will evolve cooperatively.” ^33^ Recent trends in Federal government contracting have moved away from a strict SOW process that must be followed at all costs. Relational contract theory suggests that current Federal contracting practices overemphasize fixed-pricing and bottom line price competition. ^33^ Relational contracts are well suited to the concept of the Statement of Objectives (SOO), a variation of the SOW. The SOO formally requires parties to work together to define the contractual requirements. The five-step approach to using an SOO as described by Mather and Costello requires the requesting organization (in this case, the partners) to first “conduct market research,” which would imply gathering information from all stakeholders who matter to the partner, including policymakers and patient groups, if relevant. ^34^ Second, the partner would develop an initial SOO and identify constraints that might affect the ultimate deliverable. Third, the partner (or knowledge broker) would conduct an initial competition. Fourth, the partner (or knowledge broker) would support contractors during the due diligence phase, which should take 6 weeks or more according to Mather and Costello. ^34^ Finally, a contract award would be made.

A major cause of resource problems is scope creep, which occurs when the objectives of the partner organization change midway through the project. The literature supports the importance of controlling scope creep. The Federal government contracting literature addresses the issue of scope creep through the mechanism of changes clause.

Changes clauses constitute a formal process by which scope creep can be managed. As a reflection of their importance, the changes clause is one of the most litigated clauses in government contracts. ^13^ In fixed-price supply contracts, the changes clause provides that the contracting officer may at any time, by written order, “make changes, within the general scope” of the contract. ^13^ When a contractor receives a change order, he has 30 days to submit a “proposal for adjustment;” the term “equitable adjustment” is the process by which contractors recover “the reasonable value for the work under which no agreement was reached on price [in the fixed-price contract].” ^13^

A cardinal change is a unique subset of changes to the initial contract, a modification “beyond the original scope” of the contract, which requires the contractor to perform “duties materially different from those originally bargained for.” ^13^ The Court of Claims has ruled that a cardinal change is a breach of contract, entitling the contractor to damages. Cardinal changes are considered potential attempts at “unauthorized procurement,” according to the theory of unjust enrichment, ^13^ meaning that the government (or requesting organization) is overstepping its legal bounds by attempting to derive extra benefits from the contractor.

Finally, a constructive change is a change that the contractor argues he has to make in order to meet project objectives, even though he has not received an official written change order. In other words, a constructive change is the formal process by which the contractor can change scope. It is important that a formal process for change orders be followed, because courts have not upheld oral change orders in recent years. If a contractor performs extra work without a written change order, he is considered a “volunteer.” ^13^

Research and development (R&D) contracting within the Federal government is not usually done according to fixed-price contracts. According to the Federal Acquisition Requisition (FAR) 35.005, the R&D SOW should allow contractors “freedom to exercise innovation and creativity,” and be “individually tailored.” ^35^ In R&D contracts, “the difficulties in estimating costs...normally precludes fixed-price contracting.” ^13^

A pragmatic approach for particularly complex projects, termed scope planning, is advocated in the PMBOK (Project Management Body of Knowledge). ^3^ Scope planning starts before the project charter is written and includes “the initial definition of constraints and assumptions.” A project charter is a “document issued by the project initiator or sponsor that formally authorizes the existence of the project, and provides the project manager with the authority to apply organizational resources to project activities.” ^3^ Scope definition also includes consideration of constraints and assumptions and the development of a work breakdown structure (WBS). The WBS is defined as “a deliverable-oriented grouping of project elements that organizes and defines the total work scope of the project. Each descending level represents an increasingly detailed definition of the project work.” The WBS helps enumerate tasks and sub-tasks needed to complete a project, and assigns responsibility for those tasks. It is then utilized to develop the SOW. ^2^ Scope verification is the process of “obtaining formal acceptance of the project scope by the stakeholders.” Scope change control is a formalized method of monitoring changes in scope according to pre-defined criteria for documenting the change and ensuring adequate resources to support the change. Partner advantages gleaned from scope change control include performance measurement, which are necessary “to assess the magnitude of any variations [in scope] that do occur.” ^3^

## Summary of Step 2: Literature Review

The literature review regarding the challenges to technical analysis for policymaking reinforced the general themes raised in the interviews in Step 1, and these themes fell into the categories of cultural/educational factors, strategic factors, and resource factors. The literature suggests that cultural differences are deeply rooted, are reflected in the polarizing distinction between “excellence” and “relevance,” can persist throughout an entire project if not addressed, and, if allowed to persist, can sabotage the entire effort. Strategic factors highlight the importance of a conceptual framework, and specific, well understood and communicated processes for establishing that framework, as well as roles and responsibilities. Resource factors are noted to be crucial and are more extensively addressed in the management and contracting literature, stemming from the tendency for technical assessment projects to incur “scope creep.”

Several potential solutions are offered, related to each category. To address cultural factors, approaches include education and integration, using various informal and formal techniques. To address strategic factors, suggestions include the identification and funding of a trained “knowledge transfer agent,” formal assignment of roles and responsibilities, and establishment of the definition of “non-normativity.” Problems related to resource factors can be approached with strategies such as institutionalizing a due diligence phase, and use of relational contracts, changes clauses, as well as more involved techniques such as scope planning.