# Step 1: Informant Interviews

## Informant Interview Methods

Semi-structured interviews were conducted with the three groups involved in the EPC activities: EPC staff (research center directors and project managers), AHRQ staff, and representatives from partner organizations (both public and private). Interviews were conducted by telephone, were audio-taped, and lasted about 45 minutes each. The interviews were conducted over a 2-month period by a team of three researchers. An interview guide was followed. Questions were general in nature and focused on areas related to the establishment of appropriate processes for evidence-based reporting and health technology assessment. All topics in the interview guide were covered during each interview. Interviews were conducted with 11 EPC directors, one EPC project manager, three AHRQ representatives, two Federal partners, two non-federal partners, two academic experts, and one management expert.

All interview tapes were transcribed and then read several times to identify key issues. A structured coding scheme was devised based on a reading of the transcripts and the objectives of the project; sections of text were coded to the identified themes. Coded segments were then examined and compared, first to identify similarities and differences and later to produce a conceptual framework for analysis and interpretation.

## Informant Interview Results

An analysis of the coded transcripts was organized by the three major interview topics:

1 The concept of a successful report.
2 Determinants of a successful report.
3 The role of AHRQ processes and procedures in promoting success.

Quotes presented here have been selected as typical of the perceptions and experiences recorded; they are not, however, statistically representative of a larger population.

### The Concept of a Successful Report

For researchers, success is perceived to occur at different levels. Primarily, a report is considered successful when the partners use the report (either to produce guidelines or develop policy), confirm that the report met their requirements, and provide the researchers with feedback from end users. In addition, for researchers, a successful report must be a rigorous synthesis (in accordance with evidence-based principles), intellectually satisfying, conducted using a credible synthesis of data, and provide new insights. A few researchers noted that reports should allow junior faculty in pursuit of an academic career to publish, while others did not view publication as an important endpoint. The metric by which success is measured has not been firmly established; there are some reports that, regardless of whether they have technically been good analyses or not, have either not been used to implement policy or have not received “a lot of press.” In addition to issues related to the nature of the application of the report, EPC directors generally agreed that a successful report must break even financially.

AHRQ staff also reflected on what constitutes a successful EPC report, one that blends the notions of excellence and usefulness. First, a good report has to “meet the needs” of the partners. It answers questions that the partners will find useful and have asked. It has to be an excellent, well-written synthesis of the qualitative issues related to the topic addressed, and the highest methodological standards must have been applied. A successful report shows how each piece of evidence fits together to answer a question. It has clear key questions, identifies all the relevant literature, utilizes a technical expert panel knowledgeable about the subject, incorporates clinical opinion, and demonstrates an understanding of evidence, while remaining non-normative. A successful report requires “clinical content expertise, knowledge of the technology and identification of the policy implications.”

The concept that partners have of a successful report is one that meets their needs. A successful report “includes what we told you to do.” In order to be a good report, it has to include the “universe of evidence,” not just a subset, with tables that organize evidence in a manner that is easy enough to understand so that committees can weigh the evidence themselves. They understand that in order to have a successful report, they must “have an outcome in mind.”

Our non-EPC interviewees (two academic experts in technical analysis for policymaking and one management expert) confirmed the importance of a useful report as a prime measure of success. One academic expert suggested that one should not underestimate the potential value of academic products (e.g., manuscripts and technical reports) as they may influence the way people think about a problem; this effect may be slower but potentially more profound.

### Determinants of a Successful Report

For researchers, the most important determinant for a successful report is having a well-defined scope of work. Narrow and clearly worded questions facilitate research work and make it feasible to complete the report with the available time and resources. Other major conditions are to understand the audience and the intent of the report. Researchers need explicit information to know “the context of what users are looking for.” They also need to know more about the desired structure and tone of the report (scientific vs. lay tone).

There is an overall concern among researchers, however, that these requirements are often not explicit enough or not clearly established in the original statement of work. If reports have to meet partners' needs, those needs have to be identified. “Clear expectations need to be identified by the partner.” “What they want” has to be well articulated to result in a credible product, and it has to be identified up front using relevant questions. “A crucial component is to define the scope of the project up front.” Several problems have been identified with this process. In many instances, what EPCs are asked to do is completely “out of feasible bounds.” Broad scopes and questions are the norm, not the exception. In many cases, EPCs have perceived that partners were not sure what they really wanted to do. “It took us a while to figure out what they actually wanted.” When research questions have to be refined, not only is the scientific success of the report at risk, but there can be financial implications because “budget is the concrete manifestation of a statement of work.” This problem is particularly relevant because of the strict time frame for completion of reports. Because the work with partners changes over time, some change is inevitable; researchers indicate “we need flexibility.” However, when partners do not develop a clear conceptual framework up front, the result is that questions are not specific enough and researchers cannot define the type of analysis needed.

Researchers indicated that one factor that can influence a project's success is consistency of role expectation. Specifically, it is sometimes difficult to keep up with how partners define their roles; a partner may be “hands-off” in the beginning, and then decide that it wants to be intimately involved in completing the project, or it may request that the EPC become deeply involved in dissemination and implementation aspects of the project that were beyond the initial project scope.

AHRQ recognizes that reports need to start with a well-defined conceptual framework, identifying what the problems are and where the complexities lie. Developing this conceptual framework requires time and commitment. In constructing the final report, the technical analysis often has to be adjusted to match the conceptual framework.

Partners have also identified that a major determinant of a successful report involves asking focused questions. They consider this to be their main responsibility. The partners also raised the point that this is a learning process and that they have come to recognize this through their participation. On the other hand, several partners said that they were disappointed with certain reports that were too detailed to support decisionmaking. Even if the reports were technically perfect, they did not meet the needs of the end users because they did not present information in a useful manner. Partners said it is necessary to “identify the audience for the report early,” to “show how each piece of evidence fits together to answer a question,” and to structure the evidence report so that it is facile for decisionmakers to weigh the evidence themselves.

Two other factors were generally agreed to be determinants of a successful report. The first is having an abundance of communication. All parties involved mentioned that establishing a “face-to-face relationship” is essential. Partners realize that it is crucial to have greater interaction with AHRQ and researchers in the very beginning stages of the project. “Our input can't come too late in the process.” Establishing this relationship outlines the nature and content of the report in an interactive, refined process. For researchers there is an inherent tension: “the more we want the reports to have impact, the more we have to negotiate with the partners.”

The second factor determining a successful report is the presence of a formal process for creating a standard report: establish a good working team with diverse and substantial expertise, develop collaborations with clinical and content experts, identify the literature, synthesize the evidence, and write a technically correct and readable report. The role of external experts is considered to be very helpful. The experts know who the leaders are in the field (professional societies, advocacy groups, industry), and can fill in the story behind the solicitation and agendas.

One academic expert mentioned the importance of establishing a process for dealing with especially contentious topics (e.g., independent oversight panels) in circumstances where potentially important information might otherwise be suppressed or enhanced for reasons other than good science. The management expert highlighted the importance of a well-constructed SOW; this was the only person who volunteered the SOW as a determinant of a successful report.

### The Role of AHRQ in Promoting Success

Overall, both partners and researchers indicated a high level of satisfaction with AHRQ. Respondents also indicated that, in some areas, the role of AHRQ could be enhanced in order to improve the success of EPC reports.

There is a widespread perception, both among researchers and partners, that AHRQ should mediate—or at least facilitate—the interaction between analysts and partners. “AHRQ has to make sure that the project they select creates the greatest value.” “I would be happy to see AHRQ take a stronger role in making partners prioritize questions, in order to avoid scope creep when the partner suddenly discovers he wants to ask another question.” There is a need to prioritize among all possible questions, focusing on those questions whose answers provide the greatest value. Partners have to understand that “they are going to receive what they need, but perhaps not what they want.” Researchers would like AHRQ to “push the partner to define what they want.” Partners should understand that they are receiving “an enormous gift,” but they have to be prepared to collaborate on the project and be ready to use it. They need to have an understanding of evidence-based medicine and systematic reviews. “We need to educate them.” Researchers advocate that AHRQ accomplish this work up front, “they could set the stage better with partners.” This educational process would allow for aligned expectations and a focus on the “right questions.”

From the researchers' perspective, AHRQ needs to minimize the gap between what partners want and what is expressed in the scope of work. Current mediation strategies were not seen as adequate. AHRQ has to identify “other ways of doing the intermediary work, other mechanisms.” Partners also recommended establishing a formal process, with clearly established parameters, to ensure that all issues are addressed. “We need a consistent, routinely followed process.”

All parties expressed that the process has improved over time. Earlier reports were more “painful.” Both the EPCs and AHRQ commented that the more recent reports have been better. EPCs are more experienced doing things for the price, can better estimate the amount of literature they are going to have to review, and have developed more experienced teams. While “EPCs have learned by doing,” EPCs expressed a strong desire to have more opportunity to benefit from the experience of others.

Three issues involving AHRQ were also mentioned. First among these was the existence of some variability among the different Task Order Officers overseeing the different reports in the way they conduct their work. Having a “fabulous project officer” is a key factor. A second issue was the role of the Coordinating Center. Although the establishment of the Coordinating Center raised a lot of expectations, the overall perception is that its impact is very limited at the moment. The third issue involves the budgets. The EPCs perceive that they are not receiving the funding they need to conduct their work. “This work is more than pulling together a few RCTs (randomized controlled trials).” Limited resources place a significant constraint on doing a quality job. “We need more money, more time.” This is still a largely boutique industry model and it is, consequently, quite expensive. Each product has to be developed largely from scratch, by hand. Although some standardization can help, tailoring is one of the most attractive and useful features of the EPC reports. While academic institutions seem to be better suited to find solutions (junior faculty can sometimes augment the contributions of assigned staff); for other institutions this is not always possible.

## Summary of Step 1: Informant Interviews

Three salient themes emerge from the Step 1 interviews relating to the definition of a successful report, the determinants of a successful report, and the role of AHRQ in the EPC process. These themes relate to: (1) culture/education factors; (2) strategic factors; and (3) resource factors.

Cultural factors influence the definition of a successful report as one that is used productively. Researchers and users of evidence reports often have different values, goals, and perspectives about what constitutes productive use; these are shaped by their professional cultures. The process of linking the work of researchers and users is especially challenging because it requires the meshing of two worlds. The differences relate to familiarity with the principles of evidence-based medicine on the one hand and the practical realities of clinical medicine or the exigencies of policymaking on the other. The process of identifying and synthesizing best medical evidence into policy is subject to the risk that participants do not share the same cultural foundation, experiences, and expectations. Cultural understanding must occur at an early point in the development of evidence reports—policymakers and researchers clinicians need to teach each other. Ideally, the process of mutual education should begin with a face-to-face meeting immediately after the evidence report is commissioned. Establishing trust and expectations early is essential to the success of an evidence report.

Regarding strategic issues, early development of a conceptual framework appears key to the development of a successful EPC report. A conceptual framework takes into account not only scientific evidence, but clinically relevant factors and stakeholder interests and serves as a vehicle for communication.

Finally, resource factors can strongly influence the success of any implementation effort. It has been a traditional practice for organizations seeking to develop various products (such as clinical guidelines) to rely on the goodwill of their academic grantees to provide expert input for dissemination and implementation efforts. Several EPC participants suggested that this unfortunate historical precedent caused partners to underestimate the true economic cost of an EPC evidence report. A more troubling concern raised by EPCs was scope creep—the tendency to expand the work required by the EPC—without due consideration of the costs and the implications for timely production.

Notably, the formulation or nature of the SOW was not perceived by EPC participants as an especially important aspect of a successful report, but rather seemed to be a necessary component of the EPC activity. The management expert was the only interviewee who independently noted the potentially vital importance of a well-crafted SOW in assuring a successful technical report.