# Methodological Overview

The project proceeded in four steps:

- In Step 1 we interviewed participants in the EPC process in order to establish a deeper understanding of the current process, focusing on the definition and determinants of a successful report. Although the primary goal was to understand current processes, we also solicited ideas about solutions, including strategies for producing a more useful SOW.
- In Step 2 we reviewed the technical contracting literature relating to formulating SOWs for the production of policy reports and similar intellectual products, as well as the policy literature related to the determinants of a successful policy analysis. This step was intended to complement the interviews in Step 1 by placing the EPC activities in a broader context, and particularly to identify existing concrete solutions to problems noted in the interviews.
- In Step 3 we applied the Current Reality Tree (CRT) technique from the Theory of Constraints (TOC) to synthesize the information provided in the first two steps in a way that highlights core constraints (i.e., constraints that are the most important targets for improvement.) Again, in the spirit of maintaining concreteness, we were especially attentive to distinguishing constraints that were within the control of the EPC participants. As part of this step we presented the work from Step 1 and Step 2, as well as preliminary reflections on the core constraints, at the 2004 annual EPC meeting and solicited written feedback.
- In the final step (Step 4) we reviewed the information collected in the interviews and literature review in the context of the TOC exercise. The objective was to identify promising solutions for the core constraints, which may serve as input to an action plan by AHRQ in collaboration with EPCs and partners. With these solutions in mind, we constructed a Future Reality Tree, an illustration of the impact of the proposed solutions on the EPC's SOW process.