# Introduction

In 1997, the Agency for Healthcare Research and Quality (AHRQ) created 12 Evidence-based Practice Centers (EPCs). The objective of the EPC program was to provide a public service information resource for policymakers, clinicians, and other decisionmakers. According to AHRQ, ^1^ the EPCs' mission is to “develop evidence reports and technology assessments on topics relevant to clinical, social science/behavioral, economic, and other health care organization and delivery issues.” In 2002, AHRQ announced a second 5-year cycle of funding for the program and expanded the total number of EPCs to 13.

The principal products of the EPCs are called evidence reports or technology assessments; for simplicity's sake, we refer to them here as evidence reports. EPC evidence reports are detailed evaluations of the scientific literature on specific clinical, behavioral, organizational, and financing topics of interest to policymakers, clinicians, and other decisionmakers. The reports are requested by organizations representing these interested parties. Termed “clients” in general management parlance, these organizations are called “partners” in the context of the EPC process.

From the moment an EPC report is proposed, to its production and use by a partner, all parties are engaged in a process. Like any process, the EPC process is subject to improvement. The importance of process improvement to the EPC program is reflected both in the existence and the content of the annual AHRQ meeting with EPCs and partner organizations.

Two areas have been evident targets for improvement: process efficiency and stakeholder satisfaction (where stakeholders are both direct participants in the EPC effort as well as other parties with an interest in EPC products). Process efficiency assures that the immediate goals of any EPC project are accomplished without wasting public resources. Stakeholder satisfaction directly impacts the long-term sustainability of the EPC program; stakeholders who have a sense of satisfaction in the process and the products are more likely to value and support the public service provided by the EPC program.

This report describes a project initiated by the Duke Evidence-based Practice Center to contribute to the improvement of the EPC process, focusing on specific actions that could serve to improve process efficiency and stakeholder satisfaction. To maintain a level of concreteness, we organized our efforts around the concept of a “statement of work (SOW).” As a contractual document, the SOW is the tangible manifestation of the objectives of each EPC project, serving as a foundation for interaction between involved parties, including technical details such as budget, timeline, and deliverables. A well-constructed SOW is also the keystone for clear communication and effective interaction between naturally distinct parties. It should provide a level of guidance that maximizes the chance that the final product will serve the purposes of the partner or sponsor. When poorly constructed, the SOW can lead to significant delays and can ultimately result in an unsatisfactory report.

It should be noted that while the SOW document is of potential importance, it is the concept of the SOW that is fundamental. This project is aimed at identifying strategies for enhancing the success of the EPC program; some, if not all, of the enhancements should be reflected in an improved SOW document. (For a more detailed definition of the statement of work, see Appendix.)