# Appendix Technical Description of the Statement of Work

The Statement of Work (SOW) is most fundamentally a contractual agreement stipulating how a job, in this case a research study, will be done. The Statement of Work establishes expectations and mediates the relationship between contractor and sponsor (in the case of the EPC program, between research team and AHRQ, which contracts on behalf of a “partner”). According to Michael G. Martin, author of Delivering Project Excellence with the Statement of Work, ^1^ “the single most significant cause of project failure is the lack of a clearly defined and detailed statement of work.” Martin identifies the first formal SOW written in modern history as the 1908 Army Signal Corps document entitled “Agreement and Specification for the Wright Brothers' Heavier-than-Air Flying Machine,” (though he admits that Noah's biblical instructions for building the ark essentially constituted a Statement of Work). The Department of Defense and the National Aeronautics and Space Administration (NASA) have published handbooks that describe the step-by-step process of writing a Statement of Work. ^2^ – ^4^ NASA ^4^ defines the SOW as a document that:

. . . .describes the work to be performed or the services rendered; defines the respective responsibilities of the Government and the contractor; serves as a basis for contractor response, evaluation of proposals and source selection; and ultimately provides an objective measure so that both the Government and the contractor will know when the work is satisfactorily completed and payment is justified.

Definitions from the Department of Defense and the project management literature have much in common with NASA's definition, but NASA's definition was selected for repetition here because NASA specifically addresses the responsibilities of both the contractor and the client (the Government). The SOW is not just a work plan detailing the services that the contractor (or researcher) will offer; rather, it lays the groundwork for a relationship between contractor and client.

All Federal agencies use the Federal Acquisition Regulation (FAR) to acquire needed supplies and services, and the FAR defines the SOW. One subsection of the FAR, subsection 37.602-1-Statements of Work, is given below (FAC 24, effective July 19, 2004).

FAR Subsection 37.602-1: Statements of work. ^5^

(a) Generally, statements of work shall define requirements in clear, concise language identifying specific work to be accomplished. Statements of work must be individually tailored to consider the period of performance, deliverable items, if any, and the desired degree of performance flexibility (see 11.106). In the case of task order contracts, the statement of work for the basic contract need only define the scope of the overall contract (see 16.504[a][4][iii]). The statement of work for each task issued under a task order contract shall comply with paragraph (b) of this subsection. To achieve the maximum benefits of performance-based contracting, task order contracts should be awarded on a multiple award basis (see 16.504[c] and 16.505[b]).
(b) When preparing statements of work, agencies shall, to the maximum extent practicable—
  (1) Describe the work in terms of “what” is to be the required output rather than either “how” the work is to be accomplished or the number of hours to be provided (see 11.002[a][2] and 11.101);
  (2) Enable assessment of work performance against measurable performance standards;
  (3) Rely on the use of measurable performance standards and financial incentives in a competitive environment to encourage competitors to develop and institute innovative and cost-effective methods of performing the work; and
  (4) Avoid combining requirements into a single acquisition that is too broad for the agency or a prospective contractor to manage effectively. ^5^

## References for Appendix

1 Martin, MG. Delivering project excellence with the SOW. Vienna, VA: Management Concepts; 2002.
2 Department of Defense. Handbook for preparation of statement of work (SOW). MIL-HDBK-245D. April 3, 1996. Available at: http://www.acqnet.gov/Library/OFPP/BestPractices/pbsc/library/DODhandbook.pdf. Last accessed: March 10, 2005.
3 Department of Defense. Handbook for work breakdown structure. MIL-HDBK-881. January 2, 1998. Available at: http://www.acq.osd.mil/pm/currentpolicy/wbs/mil_hdbk_881/mil_hdbk_881.htm. Last accessed: March 10, 2005.
4 NASA. Statement of Work (SOW): Guidance for writing work statements. NASA NPG 5600.2B. December 1997. Available at: http://www.hq.nasa.gov/office/procurement/newreq1.htm. Last accessed: March 10, 2005.
5 Federal Acquisition Regulation, FAC 24, July 19, 2004. Available at: http://www.arnet.gov/far/. Last accessed: March 10, 2005.