# Acronyms and Abbreviations

AHRQ | Agency for Healthcare Research and Quality
CHCF | California HealthCare Foundation
EMR | electronic medical record
FFS | fee for service
GOLD | Grants On-Line Database
GP | general practitioner
HEDIS^®^ | Health Plan Employer Data and Information Set
HMO | health maintenance organization
IDS | integrated delivery system
IOM | Institute of Medicine
JCAHO | Joint Commission on Accreditation of Healthcare Organizations
MESH | medical subject heading
MI | myocardial infarction
PCP | primary care provider
POS | point of service
PPO | preferred provider organization
QBP | quality-based purchasing
RWJF | Robert Wood Johnson Foundation
VBP | value-based purchasing