# References and Included Studies

1 Kohn LT, Corrigan J, Donaldson M, (eds). To Err is Human: Building a Safer Health Care System. Washington, D.C: National Academy Press; 1999.
2 Jha A K, Perlin J B, Kizer K W, Dudley R A. Effect of the transformation of the Veterans Affairs Health Care System on the quality of care. N Engl J Med. 2003;348(22):2218-2227. [pmid: 12773650].
3 McGlynn E A, Asch S M, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-2645. [pmid: 12826639].
4 Dudley R A, Luft H S. Managed care in transition. N Engl J Med. 2001;344(14):1087-1092. [pmid: 11287981].
5 Mehrotra A, Bodenheimer T, Dudley R A. Employers' efforts to measure and improve hospital quality: determinants of success. Health Affairs. 2003;22(2):60-71. [pmid: 12674408].
6 Bindman A B. Can physician profiles be trusted?. JAMA. 1999;281(22):2142-2143. [pmid: 10422995].
7 Hofer T P, Hayward R A, Greenfield S, Wagner E H, Kaplan S H, Manning W G. The unreliability of individual physician “Report Cards” for assessing the costs and quality of care of a chronic disease. JAMA. 1999;281:2098-2105. [pmid: 10367820].
8 Thomas J W, Hofer T P. Accuracy of risk-adjusted mortality rate as a measure of hospital quality of care. Medical Care. January. 1999;37(1):83-92. [pmid: 10413396].
9 Marshall M N, Shekelle P G, Leatherman S, Brook R H. The public release of performance data: what do we expect to gain? A review of the evidence. JAMA. 2000;283(14):1866-1874. [pmid: 10974682].
10 Marshall M N, Shekelle P G, Davies H T, Smith P C. Public reporting on quality in the United States and the United Kingdom. Health Affairs. 2003;22(3):134-148. [pmid: 12757278].
11 McLaughlin C. Health Care Consumers: Choices and Constraints. Med Care Res Rev. 1999;56(Suppl 1):24-59. [pmid: 10354678].
12 Galvin R, Milstein A. Large employers' new strategies in health care. N Engl J Med. 2002;347(12):939-942. [pmid: 12239267].
13 Wetzel S, Galvin R, Buck C J, et al. Taking a giant leap forward in promoting quality. Health Aff. 2000;19(2):275-276.
14 Jencks S F, Huff E D, Cuerdon T. Change in the quality of care delivered to medicare beneficiaries, 1998-1999 to 2000-2001. JAMA. 2003;289:305-312. [pmid: 12525231].
15 Jack W. Contracting for health services: an evaluation of recent reforms in Nicaragua. Health Policy and Planning. 2003;18(2):195-204. [pmid: 12740324].
16 Eichler R, Auxilia P, Pollock J. Performance-based payment to improve the impact of health services: evidence from Haiti. World Bank Institute Online Journal. April 15, 2001. Available at: www.worldbank.org/wbi/healthflagship/oj_haiti.pdf. Accessed February 23, 2004.
17 Corrigan JM, Donaldson MS, Kohn LT, (eds). Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, D.C: National Academy Press; 2001.
18 Hillman A L, Ripley K, Goldfarb N, Nuamah I, Weiner J, Lusk E. Physician financial incentives and feedback: failure to increase cancer screening in Medicaid managed care. Am J Public Health. Nov. 1998;88(11):1699-1701. [pmid: 9807540]. [pmcid: 1508575].
19 Miller R, Luft H. HMO plan performance update: an analysis of the literature, 1997-2001. Health Aff. 2002;21(4):63-86.
20 Dudley RA, Miller RH, Korenbrot TY, Luft HS. The impact of financial incentives on quality of health care. Milbank Q. 1998;76(4):649–686, 511.
21 Dranove D, White W D. Agency and the organization of health care delivery. Inquiry. 1987;24(4):405-415. [pmid: 2961701].
22 Robinson J C. Theory and practice in the design of physician payment incentives. Milbank Q. 2001;79(2):149-177. [pmid: 11439463].
23 Hellinger F J. The effect of managed care on quality: a review of recent evidence. Arch Intern Med. Apr 27. 1998;158(8):833-841. [pmid: 9570168].
24 Hutchison B, Birch S, Hurley J, Lomas J, Stratford-Devai F. Do physician-payment mechanisms affect hospital utilization? A study of Health Service Organizations in Ontario. CMAJ. 1996;154(5):653-661. [pmid: 8603321]. [pmcid: 1487544].
25 Andersen R M. Revisiting the behavioral model and access to medical care: Does it matter?. Journal of Health and Social Behavior. 1995;36(1):1-10. [pmid: 7738325].
26 Town R, Kralewski J, Wholey DR, Dowd B. Assessing the influence of incentives on physicians and medical groups. issue of Med Care Res Rev. 2004 (September).
27 Eisenberg JM. Doctors' decisions and the cost of medical care: the reasons for doctors' practice patterns and ways to change them. Ann Arbor, MI: Health Administration Press; 1986.
28 Feinstein A R. The ‘chagrin factor’ and qualitative decision analysis. 145 (7):1257–9. Archives of Internal Medicine. 1985;145(7):1257-1259. [pmid: 4037948].
29 Loomes G, Sugden R. Regret theory: An alternative theory of rational choice under uncertainty. 92 (368):805–824. Economic Journal. 1982;92(368):805-824.
30 Frey B S. On the Relationship between Intrinsic and Extrinsic Work Motivation. International Journal of Industrial Organization. 1997;15:427-439.
31 Kuhn M. Quality in Primary Care: Economic Approaches to Analysing Quality-Related Physician Behavior. London: Office of Health Economics; 2003 (August).
32 Christensen D B, Hansen R W. Characteristics of pharmacies and pharmacists associated with the provision of cognitive services in the community setting. J Am Pharm Assoc. (Sept-Oct). 1999;39(5):640-649.
33 Christensen D B, Holmes G, Fassett W E, et al. Influence of a financial incentive on cognitive services: CARE project design/implementation. J Am Pharm Assoc (Wash). Sep-Oct. 1999;39(5):629-639. [pmid: 10533344].
34 Kouides R W, Bennett N M, Lewis B, Cappuccio J D, Barker W H, LaForce F M. Performance-based physician reimbursement and influenza immunization rates in the elderly. The Primary-Care Physicians of Monroe County. Am J Prev Med. Feb. 1998;14(2):89-95. [pmid: 9631159].
35 Amundson G, Solberg L I, Reed M, Martini E M, Carlson R. Paying for quality improvement: compliance with tobacco cessation guidelines. Jt Comm J Qual Saf. Feb. 2003;29(2):59-65. [pmid: 12616920].
36 Newacheck P W, McManus M A, Gephart J. Health insurance coverage of adolescents: a current profile and assessment of trends. Pediatrics. Oct. 1992;90(4):589-596. [pmid: 1408514].
37 Fairbrother G, Siegel M J, Friedman S, Kory P D, Butts G C. Impact of financial incentives on documented immunization rates in the inner city: results of a randomized controlled trial. Ambul Pediatr. Jul-Aug. 2001;1(4):206-212. [pmid: 11888402].
38 Hillman A L, Ripley K, Goldfarb N, Weiner J, Nuamah I, Lusk E. The use of physician financial incentives and feedback to improve pediatric preventive care in Medicaid managed care. Pediatrics. Oct. 1999;104(4 Pt 1):931-935. [pmid: 10506237].
39 Grumbach K, Osmond D, Vranizan K, Jaffe D, Bindman A B. Primary care physicians' experience of financial incentives in managed-care systems. N Engl J Med. Nov 19. 1998;339(21):1516-1521. [pmid: 9819451].
40 Hadley J, Mitchell J M, Sulmasy D P, Bloche M G. Perceived financial incentives, HMO market penetration, and physicians' practice styles and satisfaction. Health Serv Res. Apr. 1999;34(1 Pt 2):307-321. [pmid: 10199677]. [pmcid: 1089003].
41 Pantilat S Z, Chesney M, Lo B. Effect of incentives on the use of indicated services in managed care. West J Med. Mar. 1999;170(3):137-142. [pmid: 10214099]. [pmcid: 1305530].
42 Hillman A L, Pauly M V, Kerstein J J. How do financial incentives affect physicians' clinical decisions and the financial performance of health maintenance organizations?. N Engl J Med. Jul 13. 1989;321(2):86-92. [pmid: 2733758].
43 Hickson G B, Altemeier W A, Perrin J M. Physician reimbursement by salary or fee-for-service: effect on physician practice behavior in a randomized prospective study. Pediatrics. Sep. 1987;80(3):344-350. [pmid: 3627885].
44 Landon B E, Reschovsky J, Reed M, Blumenthal D. Personal, organizational, and market level influences on physicians' practice patterns: results of a national survey of primary care physicians. Med Care. Aug. 2001;39(8):889-905. [pmid: 11468507].
45 Mort E A, Edwards J N, Emmons D W, Convery K, Blumenthal D. Physician response to patient insurance status in ambulatory care clinical decision-making. Implications for quality of care. Med Care. Aug. 1996;34(8):783-797. [pmid: 8709660].
46 Chaix-Couturier C, Durand-Zaleski I, Jolly D, Durieux P. Effects of financial incentives on medical practice: results from a systematic review of the literature and methodological issues. Int J Qual Health Care. Apr. 2000;12(2):133-142. [pmid: 10830670].
47 Wee C C, Phillips R S, Burstin H R, et al. Influence of financial productivity incentives on the use of preventive care. Am J Med. Feb 15. 2001;110(3):181-187. [pmid: 11182103].
48 Krasnik A, Groenewegen P P, Pedersen P A, et al. Changing remuneration systems: effects on activity in general practice. BMJ. 1990;300(6741):1698-1701. [pmid: 2390552]. [pmcid: 1663335].
49 Conrad D A, Cave S H, Lucas M, et al. Community care networks: linking vision to outcomes for community health improvement. Med Care Res Rev. 2003;60(4 Suppl):95-129. [pmid: 14687431].
50 Fisher E S, Wennberg J E. Health care quality, geographic variations, and the challenge of supply-sensitive care. Perspect Biol Med. 2003;46(1):69-79. [pmid: 12582271].
51 Baker L C. Managed care spillover effects. Annu Rev Public Health. 2003;24:435-456. [pmid: 12471276].
52 Nyman J A, Akhtar M R, Feldman R. Does publishing the parameters that trigger review of Medicare claims change provider behavior? Results of the parameter release study. Med Care. Oct. 1995;33(10):1022-1034. [pmid: 7475401].
53 Hellinger F J. The impact of financial incentives on physician behavior in managed care plans: a review of the evidence. Med Care Res Rev. Sep. 1996;53(3):294-314. [pmid: 10159930].
54 Hoopmann M, Schwartz F W, Weber J. Effects of the German 1993 health reform law upon primary care practitioners' individual performance: results from an empirical study in sentinel practices. J Epidemiol Community Health. 1995;49(Suppl 1):33-36. [pmid: 7561668].
55 Lurie N, Christianson J, Finch M, Moscovice I. The effects of capitation on health and functional status of the Medicaid elderly. A randomized trial. Ann Intern Med. Mar 15. 1994;120(6):506-511. [pmid: 8311374].
56 Born P H, Simon C J. Patients and profits: the relationship between HMO financial performance and quality of care. Health Aff (Millwood). Mar-Apr. 2001;20(2):167-174. [pmid: 11260940].
57 Stern R S, Juhn P I, Gertler P J, Epstein A M. A comparison of length of stay and costs for health maintenance organization and fee-for-service patients. Arch Intern Med. May. 1989;149(5):1185-1188. [pmid: 2497713].
58 Walley T, Murphy M, Codd M, Johnston Z, Quirke T. Effects of a monetary incentive on primary care prescribing in Ireland: changes in prescribing patterns in one health board 1990-1995. Pharmacoepidemiol Drug Saf. Dec. 2000;9(7):591-598. [pmid: 11338918].
59 Davidson S M, Manheim L M, Werner S M, Hohlen M M, Yudkowsky B K, Fleming G V. Prepayment with office-based physicians in publicly funded programs: results from the Children's Medicaid Program. Pediatrics. Apr. 1992;89(4 Pt 2):761-767. [pmid: 1557274].
60 Roski J, Jeddeloh R, An L, et al. The impact of financial incentives and a patient registry on preventive care quality: increasing provider adherence to evidence-based smoking cessation practice guidelines. Prev Med. Mar. 2003;36(3):291-299. [pmid: 12634020].
61 Hibbard J H, Stockard J, Tusler M. Does publicizing hospital performance stimulate quality improvement efforts?. Health Aff (Millwood). Mar-Apr. 2003;22(2):84-94. [pmid: 12674410].
62 Giuffrida A, Gosden T, Forland F, et al. Target payments in primary care: effects on professional practice and health outcome (Cochrane Review). The Cochrane Library. 2002(4).
63 Gosden T, Forland F, Kristiansen IS, et al. Capitation, salary, fee-for-service and mixed systems of payment: effects on the behaviour of primary care physicians. Cochrane Database Syst Rev. 2000(3):CD002215.
64 Jarlier A, Charvet-Protat S. Can improving quality decrease hospital costs?. Int J Qual Health Care. Apr. 2000;12(2):125-131. [pmid: 10830669].
65 Seidman J J, Bass E P, Rubin H R. Review of studies that compare the quality of cardiovascular care in HMO versus non-HMO settings. Med Care. Dec. 1998;36(12):1607-1625. [pmid: 9860052].
66 Luft H S, Hunt S S. Evaluating Individual Hospital Quality through Outcome Statistics. JAMA. May 23/30. 1986;255(20):2780-2784. [pmid: 3701992].
67 Healthcare Quality and Analysis Division. Report on Heart Attack Outcomes in California 1996-1998. Volume 1: User's Guide. Sacramento: California Office of Statewide Health Planning and Development; 2002.
68 Healthcare Quality and Analysis Division. Report on Heart Attack Outcomes in California 1996-1998. Volume 3: Detailed Statistical Results. Sacramento: California Office of Statewide Health Planning and Development; 2002.
69 Romano PS, Luft HS, Remy L. Second Report of the California Hospital Outcomes Project on Acute Myocardial Infarction. Volume Two: Technical Appendix. Sacramento, CA: California Office of Statewide Health Planning and Development; May 1996.
70 Dziuban S W J, McIlduff J B, Miller S J, Dal Col R H. How a New York cardiac surgery program uses outcomes data. Ann Thorac Surg. 1994;58(6):1871-1876. [pmid: 7979785].
71 Scanlon DP. Overcoming Barriers to managing Health and Productivity in the Workplace. In: Kessler RC, Stang PD, eds. Health and Productivity: Emerging Issues in Research & Policy. Chicago: University of Chicago Press; in press.
72 Ittner CD, Larcker DF. Coming up short on nonfinancial performance measurement. Harv Bus Rev. 2003;81(11 (Nov)):88–95, 139.