# Acknowledgments

We are grateful to our expert advisors and peer reviewers for their thoughtful comments and guidance. During the preparation of this report, Peter Broadhead was supported by The Commonwealth Fund. The views presented here are those of the authors and not necessarily those of The Commonwealth Fund, its directors, officers, or staff.