# Assessing the Usefulness of Outcome Reports

In this appendix, we review the methods and results of all the simulations performed in full detail. Some of the figures and tables are the same as those already presented in the body of the report.

## Methods for Simulations

To examine the role of random variation versus true hospital quality differences in assessing reported hospital outcomes, we developed simulations to determine how often hospitals would be mislabeled in public reports. We sought to assess how the frequency of mislabeling depended upon (a) underlying assumptions about the true differences in hospital quality and (b) different evaluation and labeling strategies. The starting point for our work was an article by Thomas and Hofer, ^1^ one of a series from this research group in which they conclude that the inherent random variation in outcomes—that is, the well-recognized phenomenon of variation around an expected mortality rate caused by chance alone and not failures of care or patient risk factors—makes the use of outcome measures for public reporting (and presumably for QBP) misleading and inaccurate. Random variation is important because most outcomes reflect rare events, e.g., a 5% mortality is relatively high for surgical procedures and 15% is high for medical admissions. Also, because most hospitals have relatively small numbers of patients for most conditions and procedures, 200 patients with a given condition is high. Moreover, patients either live or die, so there will be a distribution of mortality rates around the “true” value for a hospital. ^2^ The question is whether this random variability creates so much “noise” that it is impossible to detect the “signal” indicating truly superior or poor hospitals.

For the sake of simplicity, and because it has been done in much of the prior literature, we focus our analysis below on mortality rates. However, the same concerns about the impact of chance and the same approaches to assessing its impact apply to any of the other major outcomes of interest, from patient satisfaction to complication rates to long-term disability rates and even cost (although the specific statistical approaches are slightly different for continuous variables than for binary variables).

### General Approach to Simulation

In simulating the use of outcomes data for QBP, there are two distinct steps to assessing the impact of random variation on reported hospital performance. The first is to choose assumptions about what the population of hospitals looks like in terms of both the proportion of hospitals with good and poor quality and the difference in outcomes between these groups of hospitals. In doing this, we are assuming a hypothetical world with known hospital characteristics, recognizing that these assumptions are necessarily simplifications of the real world and are certain to be at least slightly inaccurate. (If, under the given simplifying assumptions the proposed approaches for reporting do not seem to work, as is argued by Thomas and Hofer, then they are unlikely to work in the more complex real world. On the other hand, if certain reporting approaches seem to work under plausible assumptions, further tests are then warranted to make sure they are still valuable under more realistic situations.)

The second step is to calculate, given the first assumptions, the probability that an individual hospital with known characteristics will receive a particular label (e.g., “poor” vs. “good” vs. “superior”) and how often those labels will be misapplied (e.g., that a poor quality hospital will be labeled “good”). We refer to this second function as the evaluation system, and the frequency of mislabeling is determined both by the assumptions about the hypothetical world and by the approach to evaluating hospitals. The design of an evaluation system is not a purely statistical question—it also reflects how the labels are to be used. Thus, if the label is intended to be used by itself in front page headlines one may reasonably want to be much more sure of its accuracy than if it is seen as one of many indicators that needs to be confirmed with detailed chart reviews.

The hypothetical model is a representation of what the world of hospital quality actually looks like. By varying our assumptions over a reasonable range of values, we can determine the robustness of the evaluation system. In the application of evaluations to real-world hospital outcome data, one would not know which hospitals were actually—qualitatively—poor or good in advance. The input to the evaluation system would only be the measured performance, such as mortality rate, from each hospital. It would be the job of the evaluation system to assign each hospital a label, which would hopefully reflect the true nature of the hospital's performance. Each hospital's outcomes in any given year are affected by chance; a patient may receive perfect care and die anyway; another patient may receive poor quality care yet survive. On average, however, we would expect higher death rates in poor quality hospitals.

In Thomas and Hofer's model, the hypothetical world of hospitals is composed of two groups. ^1^ Poor quality hospitals comprise 10% of all hospitals, and good quality hospitals account for the remaining 90%. The defining difference between them is the proportion of patients receiving “good processes of care” and “poor processes of care” at each hospital in each group. Thomas and Hofer apply data from the literature and a program of chart reviews in Texas in 1990 and 1991 to make a series of calculations to determine the average risk of death per patient receiving care at each type of hospital. The input parameters which feed into their model of the hospital world include the risk of death having received good care, the risk of death having received poor care, the odds of receiving poor care at a good hospital versus a poor hospital, the number of patients at the average hospital, and the proportion of hospitals that are poor, as defined above. In their model, the difference in overall mortality rates between good and poor hospitals is very small (15.3% vs. 17.3%), so it is not surprising that they find it difficult to label hospitals accurately due to the effects of random variation.

A graphical representation of this hypothetical world of hospitals is shown in Figure C 1.

Figure C 1. Hypothetical World of Hospitals

To label hospitals, Thomas and Hofer use an evaluation system similar to clinical diagnostic tests. They define poor performance as that which would be found in the tails of a distribution normally distributed about the mean hospital performance. In their trials, they used a 5% cutoff, so performance likely to occur by chance in only 5% of situations was labeled as being an “outlier.” As outliers can occur both in the poor performance tail and in the superior performance tail, only 2.5% of hospitals would be labeled “poor.” The value for mortality data, above which 2.5% of hospital performance would be expected to occur is called the high trim point. ^1^ The evaluation system is summarized graphically in Figure C 2, which is adapted from Thomas and Hofer.

Figure 2 Hypothetical World and Evaluation Function (adapted from Thomas and Hofer ^1^ )

In summary, the evaluation system inputs are only the mean performance of hospitals (something observable), the number of patients seen in each hospital, and a given year's mortality data for the particular hospital. With these data, the evaluation system generates a label of “poor quality” if the mortality rate of the given hospital is greater than the trim point and “good quality” if the result is less than the trim point. Note that this approach simulates the real world in which an evaluator tries to grade hospital outcomes given only the hospital performance data. He/she does not know a priori which hospitals truly have poor or good quality. That is, only the summary solid curve describing the observed mortality rates for all hospitals in Figure C 2 and the trim point are known; the dashed lines are not known in the real world, but are used only to create the hypothetical world, upon which the grading function is tested. Furthermore, there may not be data from the hundreds or thousands of hospitals needed to plot the type of smooth solid curve shown. Instead, one may merely have a good estimate of the overall risk-adjusted mortality rate and then assume a normal distribution.

### Enhancements to the Thomas and Hofer Model

In our simulations, we enhanced the Thomas and Hofer approach in three ways. First, we increase the sophistication of the assumptions about what the underlying hospital population looks like, allowing for the existence of hospitals with superior quality and drawing our estimates of the percentage of “poor”, “good”, and “superior” hospitals from more recent data. We then consider alternative assumptions for input parameters for the evaluation system and use more sophisticated grading functions—including multi-category grading and evaluation over time.

The first enhancement to the Thomas and Hofer model investigated was the addition of a third sub-group: “superior quality hospitals.” Based on published California data from 1996-1998 showing approximately 10% of hospitals had been labeled “worse than expected” and 10% had been labeled “better than expected”, we altered the hypothetical world of hospital performance to include 10% poor quality, 10% superior quality, and 80% good or expected quality hospitals. Furthermore, hospitals labeled “better than expected” had been shown in validation studies to have superior processes of care compared to hospitals labeled “worse than expected”. Thus, although a simplification (hospital performance is likely aligned along a spectrum, rather than divided into only three groups), these results support the assumption of a distribution of hospital performance that included 10% poor quality, 10% superior quality, and 80% good (or expected) quality hospitals. ^3,^ ^4^

We obtained estimates of probability of death at poor, good, and superior quality hospitals using three-year grouped data published in the California study of acute myocardial infarction outcomes. ^3,^ ^4^ Hospitals that were consistently—over two or three studies—i.e. six or nine years—found to be statistically significantly better than the mean performance of California hospitals were included in the group of superior hospitals. Those hospitals with consistent performance below the mean were used to form the poor group. The remaining hospitals—those whose performance was not consistently and statistically different from average over two or three study periods—formed the “good” or “expected” group. The characteristics of these groups are shown in Table C 1, Scenarios 3 through 6.

Table C1. The Six Scenarios Simulated

Scenario # | Hypothetical (Defined) World of Hospitals | | | | | | | Grading Function
| Superior Quality | | Good Quality | | Poor Quality | | Average Number of Patients per Hospital | Mean probability mortality of whole population | Low Trim Point< Labeled superior | High Trim Point> Labeled poor
| True Probability of Mortality | % Total Hospitals | True Probability of Mortality | % Total Hospitals | True Probability of Mortality | % Total Hospitals
1 | Only 2 Groups | | 15.3% | 90% | 17.3% | 10% | 200 | 1 tail distribution: grade is either “good” or “poor”, i.e. if outcome is > high trim point, which includes 2.5% of population
| Recreation of Thomas and Hofer model, as starting point. | | | | | | | 15.5% | N/A | 20.5%
2 | 13.3% | 10% | 15.3% | 80% | 17.3% | 10% | 200 | 2 tails: with ~2.5% of population above/below each;
| Thomas and Hofer model; now with three groups; mortality rate for “superior” calculated using assumption that superior hospitals are as much better than good quality hospitals as poor quality hospitals are worse than good quality hospitals (i.e. rate at superior hospitals = rate at good quality hospitals - (rate at poor quality hospitals - rate at good quality hospitals); also assume 10% of hospitals are superior quality. | | | | | | | 15.3% | 10.3% | 20.3%
3 | 8.6% | 10% | 12.2% | 80% | 17.1% | 10% | 200 | 2 tails: with ~2.5% of population above/below each; mortality outcomes above high trim point labeled “poor,” below low trim point labeled “superior.”
| | | | | | | | 12.1% | 7.6% | 16.6%
| Mortality values from California AMI study (see text), using Thomas and Hofer hospital group proportions.
4 | 8.6% | 10% | 12.2% | 80% | 17.1% | 10% | 100 | 2 tails: with ~2.5% of population above/below each
| | | | | | | | 12.1% | 5.7% | 18.5%
| As above except number of patients per hospital = 100
5 | 8.6% | 10% | 12.2% | 80% | 17.1% | 10% | 100 | 2 tails: with ~10% of population above/below each
| | | | | | | | 12.1% | 7.9 | 16.3
| As above; number of patients per hospital = 100
6 | 8.6% | 10% | 12.2 | 80% | 17.1 | 10% | 400 | 2 tails: with ~10% of population above/below each trim point.
| | | | | | | | 12.1% | 10.0% | 14.2%
| As above; number of patients per hospital = 400

We believe these assumptions are a reasonable starting point for building a hypothetical world of truly poor, good, and superior hospital quality. We assume that the risk adjustment model used in the California report does not have substantial biases. Additionally, hospitals labeled “better than expected” were found in validation studies to have superior processes of care compared to hospitals labeled “worse than expected.” ^5^

Changes were then made in the evaluation or scoring system used to label a set of outcome results as either “superior,” “good,” or “poor.” We assessed the accuracy of labeling using two tailed outliers, so that we could recognize and label hospitals with superior outcomes (i.e. hospitals with measured risk adjusted mortality below the trim point are labeled “superior”) as well as those with poor outcomes. We then repeated these assessments with different outlier trim points—trimming from 2.5% – 10% into each tail, such that with two tailed trim points, either 5% or 20% of hospitals would be labeled as either “poor” or “superior.” We also ran simulations using 1, 2, and 3-year evaluations, such that each hospital would receive labels for each of 3 years. The sum of the annual grades over the 3-year period would serve as a “meta-score.” For simplicity, a star system was employed, in which a grade of “poor” was assigned 1 star, a grade of “good” received 2 stars, and a grade of “superior” earned 3 stars. The minimum 3-year score for a given hospital is therefore 3 stars (obtained by receiving only 1 star in each of the 3 years); the maximum is 9 stars.

To calculate multiple year probabilities, the probability for each score for one year was calculated for each hospital group as described above. Then, all possible combinations (order not important) of grades for 2 or 3 years was enumerated, and the cumulative probability that a given number of each grade was assigned was calculated by multiplying the appropriate probabilities for each grade. The results were then tabulated by hospital group (corresponding to sensitivity and specificity measures) and then by score assigned (corresponding to predictive errors).

Table C 1 summarizes the six scenarios that will be simulated.

## Results of Simulations

### Scenario 1: Reproducing Thomas and Hofer

For this scenario, we reproduced in our model the assumptions of Thomas and Hofer. The probability of death at poor and good hospitals was calculated as in their model as described in an unpublished appendix to their paper. The scenario is summarized by Figure C 1 and Figure C 2 above, and Table C 2 and Table C 3, below.

Table C2. Scenario 1: Predictive Values, Year 1

Score assigned | Hospital really is | Probability in whole distribution | Probability within this group of scores | 2 category test clinical test labels
Poor | Poor | 1.1% | 38.7% | Positive Predictive Value
| Good | 1.8% | 61.3% | Predictive Error
| Subtotal | 2.9%
Good | Poor | 8.9% | 9.1%
| Good | 88.2% | 90.9% | Negative Predictive Value
| Subtotal | 97.1%

Table C3. Scenario 1, Year 1: Sensitivity and Specificity Calculations

Hospital really is… | Score assigned | Probability in whole distribution | Probability within this group of hospitals | 2 category test clinical test labels
Poor | Poor | 1.1% | 11.2% | Sensitivity
| Good | 8.9% | 88.8%
| Subtotal | 10.0%
Good | Poor | 1.8% | 2.0%
| Good | 88.2% | 98.0% | Specificity
| Subtotal | 90.0%

Notice that in this scenario, a fairly large part of the poor quality hospital distribution is intersected by the trim point (Figure C 2). Examining the areas under the good quality and poor quality hospital curves, to the right of the trim point, it appears that some hospitals that are labeled poor, may in fact be of good quality. This error is called predictive error, and is reported in Table C 2. Other predictive values—positive predictive value (the chance that a hospital which received a poor grade is actually a poor quality hospital) and negative predictive value (the chance that a hospital receiving a good grade is actually a good quality hospital)—are shown as well. In the calculation of predictive values, the proportion of the two populations is important. The more rare the condition or state of being “positive” is (in this case, being a poor quality hospital), the higher the positive predictive value will tend to be. Since the poor quality hospitals only comprise 10% of the population, and their distribution is nearly subsumed by the good quality hospitals, it is not surprising that the positive predictive value is so low, and the inversely-related predictive error is so high.

Other metrics of test performance are sensitivity and specificity. The measures are independent of the population (or, in this case, hypothetical world of hospitals) in which they are used. They are measures of the tests themselves, and can be used to compare one test with another. To calculate sensitivity and specificity, a gold standard measure must be used to identify a priori the group to which the individual or organization tested in fact belongs (in our case, as the hypothetical world is defined by us, the gold standard measure is simply the hypothetical world groupings). Table C 3 shows sensitivity and specificity for scenario 1.

We can see that while the evaluation function will correctly label 98% of good hospitals as good, it will detect only 11.2% of poor quality hospitals in any given year, using Thomas and Hofer's assumptions.

Assessing the Evaluation System over Multiple Years of Use. The results for calculating star scores for 2 years are shown in Table C 4 and Table C 5. While predictive values, sensitivity, and specificity are generally defined for tests/functions with dichotomous results, the approach of each can be used with more than one possible outcome. We will examine the predictive value and sensitivity and specificity of the most extreme grades: 2 stars and 4 stars over 2 years.

Table C4. Scenario 1: Probability, Given that a Hospital Has Received Two, Three, or Four Stars over 2 Years, that It is Good vs. Poor

Number of stars (over 2 years) | Probability of actually being poor is… | Probability of actually being good is… | Overall probability of receiving score
2 | 78.2% | 21.8% | 0.2%
3 | 36.4% | 63.6% | 5.4%
4 | 8.4% | 91.6% | 94.4%

Table C5. Scenario 1: Expected Score Distribution over 2 Years

| Probability (%) hospital will receive score of…
Hospital really is… | 2 stars | 3 stars | 4 stars | Overall probability of being in this group
Poor | 1.2% | 19.8% | 78.9% | 10.0%
Good | 0.0% | 3.8% | 96.1% | 90.0%

For example, the positive predictive value of 2 stars is 78.2%—a large improvement over the 1-year figure of 38.7%, although only a small set of hospitals will be assigned this grade (0.2%); 4 stars has a negative predictive value of 91.6%; 3 stars has poor discrimination between subgroups, although a hospital in this group is more than three times more likely to truly be poor than if one selected a hospital without any performance information (this would be essentially random and would have a 10% chance of yielding a poor hospital, since they are 10% of the general population, but 36.4% of the population receiving 3 stars).

Sensitivity and specificity calculations show that specificity of 4 stars is 96.1% and sensitivity of 2 stars is only 1.2%, as 2 stars is very unlikely in this scenario, whether the hospital is poor or good.

The results for 3 years of testing in this scenario are shown graphically in Figure C 3 and by hospital group in Table C 6.

Table C6. Scenario 1: Expected Score Distribution for Good vs. Poor Hospitals over 3 Years

Hospital really is… | Probability (%) the hospital will receive score of…
| 3 stars | 4 stars | 5 stars | 6 stars
Poor | 0.1% | 3.3% | 26.4% | 70.1%
Good | 0.0% | 0.1% | 5.7% | 94.2%

Figure C3 Scenario 1: Percentage of Good vs. Bad Hospitals by 3-Year Star Score

Hospitals with 3 or 4 stars are almost certainly of poor quality—but these scores are rare. Indeed, it is a rare thing to be graded poor in this scenario, and to have it occur even once in 3 years happens for only 8.2% of hospitals.

Figure C4 Scenario 1: Expected 3-Year Score Distribution for Good vs. Poor Hospitals

### Scenario 2: Adding Another Hospital Category

For this scenario, we added the superior quality hospital group as 10% of the hypothetical hospital population. The average mortality rate for superior hospitals was assumed to be the same percentage difference below the mean performance as Thomas and Hofer's poor quality hospitals were above the mean (Table C 1). The mortality rates are shown in Figure C 5.

Figure C5 Scenario 2: Hypothetical World

The trim points were calculated using the normal distribution based on the average mortality rate with trim points defined so that 2.5% of hospitals would lie under the curve beyond each trim point (in a normal distribution with standard deviation defined by the number of patients per average hospital: 200). These assumptions about trim points and populations are shown graphically in Figure C 6.

Figure C6 Scenario 2: Hypothetical World and Evaluation Function

Year 1 results now do not have two-value predictive values, sensitivity, and specificity. Instead, the analogous computations are made by score (for predictive values) or by hospital sub-group (for sensitivity and specificity probabilities).

In the 2-year analysis (see Figure C 7), we see that hospitals earning 5 or 6 stars are all good or superior quality hospitals. The score of 4 stars is likely to include hospitals of all types. Low scores eliminate the possibility that the graded hospital is superior. However, since nearly 90% of hospitals receive 4 stars, this evaluation system does not discriminate well among the majority of hospitals.

Figure C7 Scenario 2: Proportion of Superior, Good, and Poor Hospitals by 2-Year Star Score

Three-year star scores (see Figure C 8) again reliably identify a handful of hospitals at the extremes of mortality scores. The score of 6 stars occurs 82.6% of the time, and still includes most of the poor and superior quality hospitals, as well as a large majority of the good hospitals. So, while repeating the scores allows for excellent discrimination of a small number of hospitals (that is, those few with extreme scores have a high chance of being poor or superior), the large majority of hospitals are still not reliably distinguished from average performance.

Figure C8 Scenario 2: Proportion of Superior, Good, and Poor Hospitals by 3-Year Star Score

Derivative scores were used to assess whether further discrimination could be obtained among the three sub-groups. The measures are never poor (= 0 P), ever poor (>= 1 P), exactly 1 poor (= 1 P), mostly poor (>= 2 P), never superior (= 0 S), ever superior (>= 1 S), exactly 1 superior (= 1 S), and mostly superior (>= 2S). The derivative scores for scenario 2 are shown in Figure C 9.

Figure C9 Scenario 2: Proportion of Poor, Good, and Superior Hospitals with Each Type of Derivative Score

The ever poor and ever superior scores do eliminate the superior and poor quality hospitals, respectively. However, these scores do not discriminate well between poor and good, or superior and good, respectively. Mostly poor and mostly superior have high discrimination, but only a trivial number of hospitals actually receive these grades.

Scores for each given hospital group are also summarized in Figure C 10. These results are analogous to sensitivity and specificity calculations for two value evaluations. These results show that poor hospitals generally receive scores below 7 stars and superior hospitals receive 6 stars or greater.

Figure C10 Scenario 2: Expected Distribution of 3-Year Star Scores by Hospital Type

Analysis of scenario 2 demonstrated that there could be some improvements to the labels generated by the evaluation system through the addition of multiple year scoring, and more subgroups, and therefore grading categories. However, the underlying hypothetical world has such great overlap between the two relatively rare outcomes of superior or poor quality, that discrimination is almost by definition difficult. The next scenarios explore using more realistic assumptions about variation in hospital performance to generate the hypothetical world.

### Scenario 3: Updating Assumptions about the Hypothetical Distribution of Hospital Quality

For this scenario, the underlying hypothetical hospital model used mortality data obtained from the 1996-1998 California study of risk-adjusted mortality from acute myocardial infarction. ^3,^ ^4^ See Appendix B for the algorithm used to generate the mean mortality for each group.

The model world is shown in Figure C 11 and the evaluation function is summarized in Figure C 12. The evaluation function is based on the reported population mean mortality rate and 2.5% trim points, as described above.

Figure C11 Scenario 3: Hypothetical World

Figure C12 Scenario 3: Hypothetical World and Evaluation Function

The greater difference between mortality rates in the superior and poor groups has resulted in better discrimination in 2 year scores (see Figure C 13). A large majority of poor hospitals have scores of 2 or 3 stars, while many superior hospitals receive scores of 5 or 6 stars, and these extreme scores effectively eliminate hospitals from the other end of the performance spectrum. While 4 stars still is most likely to correspond to a good quality hospital, now less than 70% of scores is 4 stars.

Figure C13 Scenario 3: Proportion of Superior, Good, and Poor Hospitals by 2-Year Star Scores

Three-year analysis also shows further improved discrimination (see Figure C 14).

Figure C14 Scenario 3: Proportion of Superior, Good, and Poor Hospitals by 3-Year Star Score

Derivative scores also show some promise in this scenario (Figure C 15). There are more hospitals in the very reliably predictive mostly poor and mostly superior categories.

Figure C15 Scenario 3: Three-Year Derivative Scores, Predictive Values

For each hospital group, the distribution of scores is summarized in Figure C 16 (which shows the proportion of all hospitals assigned each score, by group) and in Figure C 17 (which shows the proportion of hospitals within each group assigned each score).

Figure C16 Scenario 3: Expected Distribution of 3-year Star Scores by Hospital Type

Figure C17 Scenario 3: Expected Distribution of 3-Year Star Scores by Hospital Type

Specificity analysis of ever poor (Figure C 18) reflects the likelihood that a hospital of either good or superior quality could ever be incorrectly labeled poor, even once during the 3-year analysis. Superior hospitals are very unlikely to ever receive a poor score. Good hospitals can infrequently (8.7% of the time) receive one or more poor scores (only 0.3% will receive two poor scores). Poor hospitals almost always (92.5%) receive at least one poor score.

Figure C18 Scenario 3: In 3 Years Ever Graded Poor vs. Never Graded Poor

### Scenario 4: Fewer Patients per Hospital (N = 100)

This scenario explores N: the role of number of patients per hospital. This parameter is part of both the model of the hypothetical hospital world and the evaluation function, in that it is used to calculate the standard deviation for all hospital distributions. Decreasing N makes the distributions of each group wider; the trim points are further out, as seen in Figure C 19.

Figure C19 Scenario 4: Hypothetical World and Evaluation Function

The results for this scenario (Figure C 20) show that the star scores are robust over even fairly small sample sizes

Figure C20 Scenario 4: Proportion of Superior, Good, and Poor Hospitals by 3-Year Star Score

Score distributions for each hospital group are summarized in Figure C 21.

Figure C21 Scenario 4: Expected Distribution of 3-Year Star Scores by Hospital Type

### Scenario 5: Identifying a Higher Proportion of Outliers

In this simulation, the same hypothetical world as in scenario 4 was used; however, the definition of the trim points for the grading function was changed. In this scenario, the trim points are set such that 10% of the overall hospital quality distribution lies to the right of the upper trim point, and 10% lies below the lower trim point (see Figure C 22).

Figure C22 Scenario 5: Hypothetical World and Evaluation Function

Analysis of scores over 3 years (Figure C 23) shows that by relaxing the trim points, the distribution of scores is spread out as well. There are more hospitals receiving extreme grades. While the more extreme scores are still quite discriminating, there is a very small population of superior hospitals which would now receive 5 stars.

Figure C23 Scenario 5: Proportion of Superior, Good, and Poor Hospitals by 3-Year Star Score

Derivative scores results show (Figure C 24) more hospitals in the useful mostly poor and mostly good categories. It is still quite rare for a superior hospital to be mislabeled as poor—as evidenced by the ever poor (>= 1 P) predictive values.

Figure C24 Scenario 5: Three-Year Derivative Scores, Predictive Values

Scores by hospital group (Figure C 25) confirm this observation. Note that, despite the larger tails there chance that superior hospitals will have grades less than 6 stars, or poor hospitals will have grades better than 6 stars, is almost zero. Grades of 3, 4, 5, 7, 8, and 9 stars are therefore useful for at least categorizing hospitals as not poor or not superior.

Figure C25 Scenario 5: Expected Distribution of 3-Year Star Scores by Hospital Type

### Scenario 6: More Patients per Hospital

This scenario is identical to scenario 5, except that the number of patients per hospital is increased to 400. Results for 3-year analyses are shown in Figure C 26, Figure C 27, and Figure C 28. We see that with greater numbers of patients at each hospital, there can be significant improvement in the ability of the evaluation system to discriminate among classes of hospitals. Using reasonable assumptions for differences in risk-adjusted mortality rates, poor hospitals will receive 3 or 4 stars; superior hospitals 7, 8, or 9 stars (with the vast majority receiving 8 or 9), and good hospitals receive 4–8 stars, but the majority are concentrated in 5–7 stars.

Figure C26 Scenario 6: Proportion of Superior, Good, and Poor Hospital by 3-Year Star Score

Figure C27 Scenario 6: Three-Year Derivative Score Predictive Values

Figure C28 Scenario 6: Expected Distribution of 3-Year Star Scores by Hospital Type

## References for Appendix C

1 Thomas J W, Hofer T P. Accuracy of risk-adjusted mortality rate as a measure of hospital quality of care. Medical Care. January. 1999;37(1):83-92. [pmid: 10413396].
2 Luft H S, Hunt S S. Evaluating Individual Hospital Quality through Outcome Statistics. JAMA. May 23/30. 1986;255(20):2780-2784. [pmid: 3701992].
3 Healthcare Quality and Analysis Division. Report on Heart Attack Outcomes in California 1996-1998. Volume 1: User's Guide. Sacramento: California Office of Statewide Health Planning and Development; 2002.
4 Healthcare Quality and Analysis Division. Report on Heart Attack Outcomes in California 1996-1998. Volume 3: Detailed Statistical Results. Sacramento: California Office of Statewide Health Planning and Development; 2002.
5 Romano PS, Luft HS, Remy L. Second Report of the California Hospital Outcomes Project on Acute Myocardial Infarction. Volume Two: Technical Appendix. Sacramento, CA: California Office of Statewide Health Planning and Development; May 1996.