# Quality-based Purchasing Technical Expert Panel and Peer Reviewers

- David Atkins
- Chief Medical Officer
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality

- Anne-Marie Audet
- Assistant Vice President, Quality Improvement
- The Commonwealth Fund

- John Bott *
  * Member of Technical Expert Panel
- Value Based Purchasing Manager
- Employer Health Care Alliance Cooperative

- Douglas A. Conrad
- Director, Center for Health Management Research
- University of Washington

- Janet Corrigan
- Division of Health Care Services
- Institute of Medicine

- Judith Hibbard
- Professor, Department of Planning, Public Policy and Management
- University of Oregon

- Donna Marshall *
- Executive Director
- Colorado Business Group on Health

- Peggy McNamara
- Senior Analyst
- Center for Delivery, Organization and Markets
- Agency for Healthcare Research and Quality

- Arnold Milstein *
- Managing Director
- William M. Mercer

- Ann Robinow *
- President and Chief Executive Officer
- Patient Choice Healthcare

- Dennis Scanlon
- Assistant Professor
- Department of Health Policy and Administration
- The Pennsylvania State University

- Stephen Schoenbaum *
- Senior Vice President
- The Commonwealth Fund

- Laura Tollen *
- Senior Policy Consultant
- Kaiser Permanente Institute for Health Policy