# Appendixes

Appendix A Quality-based Purchasing Technical Expert Panel and Peer Reviewers

Appendix B General Approach to Simulations

Appendix C Assessing the Usefulness of Outcome Reports