# Exhibits

Exhibit 1: Initial Review Form

Exhibit 2: Abstract Review Form Used by Research Design Team (RDT) in First Round Review

Exhibit 3: Abstract Review Form Used by Research Design Team (RDT) in Second Round Review

Exhibit 4: Data Collection Form