# Evidence Tables

Natural History/Epidemiology

Risk Factors for Colorectal Cancer

Performance - Fecal Occult Blood Testing (FOBT)

Performance - Barium Enema

Performance - Colonoscopy

Performance - Sigmoidoscopy

Effects of Screening and Surveillance

Costs and Cost Effectiveness

Compliance - All Tests