# Bibliography

Ahlquist DA, Wieand HS, Moertel CG, et al. Accuracy of fecal occult blood screening for colorectal neoplasia. A prospective study using Hemoccult and HemoQuant tests. JAMA. 1993;269:1262-7. [pmid: 8437303].
Alexander GA. Cancer control in special populations: African-Americans, Native Americans, Hispanics, Poor and Underserved. In: Greenwald P, Kramer BS, Weed DL, eds. Cancer prevention and control, pp. 371-91. New York: Marcel Dekker Inc.
Allison JE, Tekawa IS, Ransom LJ, Adrain AL. A comparison of fecal occult-blood tests for colorectal cancer screening. N Engl J Med. 1996;334:155-9. [pmid: 8531970].
American Cancer Society. Cancer facts and figures, 1996. Atlanta: American Cancer Society; Publication No. 5008-96. 1996.
American Society for Gastrointestinal Endoscopy, Technology Assessment Committee. Transmission of infection by gastrointestinal endoscopy. Manchester, MA. April 1993.
American Society for Gastrointestinal Endoscopy. Antibiotic prophylaxis for gastrointestinal endoscopy. Manchester, MA; ASGE Publication No. 1027. May 1995.
American Society of Colon and Rectal Surgeons,. Practice parameters for antibiotic prophylaxis to prevent infective endocarditis or infected prosthesis during colon and rectal endoscopy. Dis Colon Rectum. 1992;35:278-85. [pmid: 1740078].
American Society of Colon and Rectal Surgeons,. Practice parameters for the detection of colorectal neoplasms. Dis Colon Rectum. 1992;35:389-90. [pmid: 1582363].
Anderson LM, May DS. Has the use of cervical, breast, and colorectal cancer screening increased in the United States?. Am J Public Health. 1995;85:840-2. [pmid: 7762721]. [pmcid: 1615482].
Anderson ML, Heigh RI, McCoy GA, et al. Accuracy of assessment of the extent of examination by experienced colonoscopists. Gastrointest Endosc. 1992;38:560-3. [pmid: 1397910].
APIC Guidelines Committee. APIC guidelines for infection prevention and control in flexible endoscopy. Am J Infect Control. 1994;22:19-38. [pmid: 8172372].
Atkin WS, Morson BC, Cuzick J. Long-term risk of colorectal cancer after excision of rectosigmoid adenomas. N Engl J Med. 1992;326:658-62. [pmid: 1736104].
Axon ATR. Cancer surveillance in ulcerative colitis--a time for reappraisal. Gut. 1994;34:587-8. [pmid: 8200547].
Baille J, Ravich WJ. On endoscopic training and procedural competence. Ann Intern Med. 1993;118:73-4. [pmid: 8416163].
Baker S. Alterman D. False-negative barium enema in patients with sigmoid cancer and coexistent diverticula. Gastrointest Radiol. 1985;10:171-3. [pmid: 3996833].
Baquet CR, Hunter CP. Patterns of minorities and special populations. In: Greenwald P, Kramer BS, Weed DL, eds. Cancer prevention and control. New York: Marcel Dekker Inc.1995.
Barry MJ, Mulley AG, Richter JM. Effect of workup strategy on the cost-effectiveness of fecal occult blood screening for colorecal cancer. Gastroenterology. 1987;93:301-10. [pmid: 3109993].
Bat L, Pines A, Ron E, et al. A community-based program of colorectal screening in an asymptomatic population: Evaluation of screening tests and compliance. Am J Gastroenterol. 1986;81:647-51. [pmid: 3740023].
Bat L, Pines A, Shemesh E, et al. Colonoscopy in patients aged 80 years or older and its contribution to the evaluation of rectal bleeding. Postgrad Med J. 1992;68:355-8. [pmid: 1630980]. [pmcid: 2399402].
Beard CM, Spencer RJ, Weiland LH, et al. Trends in colorectal cancer over half a century in Rochester, Minnesota, 1940-89. Ann Epidemiol. 1995;5:210-4. [pmid: 7606310].
Bernstein MA, Feczko PJ, Halpert RD, et al. Distribution of colonic polyps: Increased incidence of proximal lesions in older patients. Radiology. 1985;155:35-8. [pmid: 3975415].
Blalock SJ, DeVellis BM, Sandler RS. Participation in fecal occult blood screening:A critical review. Prev Med. 1987;16:9-18. [pmid: 3547387].
Blatt LJ. Polyps of the colon and rectum:Incidence and distribution. Dis Colon Rectum. 1961;4:277-82.
Bloomfield JA. Reliability of barium enema in detecting colonic neoplasia. Med J Austr. 1981;1:631-3.
Bohlman TW, Katon RM, Lipshutz GR, et al. Fiberoptic pansigmoidoscopy: An evaluation and comparison with rigid sigmoidoscopy. Gastroenterology. 1977;72:644-9. [pmid: 838219].
Bolt RJ. Sigmoidoscopy in detection and diagnosis in the asymptomatic individual. Cancer. 1971;28:121-2. [pmid: 5110616].
Bostick RM, Sprafka JM, Virning BA, Potter JD. Knowledge, attitudes and personal practices regarding prevention and early detection of cancer. Prev Med. 1993;22:65-85. [pmid: 8475013].
Brandeau ML, Eddy DM. The workup of the asymptomatic patient with a positive fecal occult blood test. Med Decis Making. 1987;7:32-46. [pmid: 3100902].
Brewster NT, Grieve DC, Saunders JH. Double-contrast barium enema and flexible sigmoidoscopy for routine colonic investigation. Brit J Surg. 1994;8:445-7.
Brostrom, O. Ulcerative colitis in Stockholm County--a study of epidemiology, prognosis, mortality and cancer risk with special reference to a surveillance program. Acta Chir Scand Suppl. 1986;534:1-60. [pmid: 3472421].
Brown JR, Conley JL, eds. Colon cancer study. Harrisburg: Physician Insurers Association of America. 1991.
Brown ML, Potosky AL, Thompson GB, Kessler LG. The knowledge and use of screening tests for colorectal and prostate cancer: Data from the 1987 National Health Interview Survey. Prevent Med. 1990;19:562-74.
Burt RW, Bishop DT, Cannon LA, et al. Dominant inheritance of adenomatous colonic polyps and colorectal cancer. N Engl J Med. 1985;312:1540-4. [pmid: 4000184].
Burt RW, Bishop DT, Lynch HT, et al. Risk and surveillance of individuals with heritable factors for colorectal cancer. Bull WHO. 1990;68:655-65. [pmid: 2289301].
Byrd RL, Boggs HW Jr, Slagle GW, Cole PA. Reliability of colonoscopy. Dis Colon Rectum. 1989;32:1023-5. [pmid: 2591276].
Cali RL, Pitsch RM, Thorson AG, et al. Cumulative incidence of metachronous colorectal cancer. Dis Colon Rectum. 1993;36:388-93. [pmid: 8458267].
Canadian Task Force on the Periodic Health Examination. The periodic health examination. Can Med Assoc J. 1979;121:1193-254. [pmid: 115569]. [pmcid: 1704686].
Cass OW, Freeman ML, Peine CJ, et al. Objective evaluation of endoscopy skills during training. Ann Intern Med. 1993;118:40-3. [pmid: 8416157].
Centers for Disease Control and Prevention. Morbidity and Mortality Weekly Report. Atlanta, GA; Centers for Disease Control and Prevention. February 9, 1996.
Centers for Disease Control and Prevention. Screening for colorectal cancer--United States, 1992-1993, and new guidelines. MMWR. 1996;45:107-10. [pmid: 8592492].
Concept approval granted to trial of prostate, lung, colorectal and ovarian screens. Cancer Letter. 1989;15:1-3.
Cordis Jr JWV, Johnson Jr H. Anatomic distribution of colonic cancers in middle-class black Americans. J Natl Med Assoc. 1991;83:730-2. [pmid: 1956086]. [pmcid: 2627127].
Dajani AS, Bisno AL, Chung KJ, et al. Prevention of bacterial endocarditis. Recommendations by the American Heart Association. JAMA. 1990;264:2919-22. [pmid: 2146414].
Dent OF, Bartrop R, Goulston KJ, Chapuis PH. Participation in fecal occult blood screening for colorectal cancer. Soc Sci Med. 1983;17:17-23. [pmid: 6844949].
Devesa SS, Chow WH. Variation in colorectal cancer incidence in the United States by subsite of origin. Cancer. 1993;71:3819-26. [pmid: 8508350].
Dodd G. The role of the barium enema in the detection of colonic neoplasms. Cancer. 1992;66:1272-5. [pmid: 1511375].
Dubow RA, Katon RM, Benner KG, et al. Short (35-cm) versus long (60-cm) flexible sigmoidoscopy: A comparison of findings and tolerance in asymptomatic patients screened for colorectal neoplasia. Gastrointest Endosc. 1985;31:305-8. [pmid: 4043682].
Durdey P, Weston PMT, Williams NS. Colonoscopy or barium enema as initial investigation of colonic disease. Lancet. 1987;5:549-51. [pmid: 2890043].
Eckardt VF, Fuchs M, Kanzier G, et al. Follow-up of patients with colonic polyps containing severe atypic and invasive carcinoma. Cancer. 1988;61:2552-7. [pmid: 3365674].
Eddy DM. Screening for colorectal cancer. Ann Intern Med. 1990;113:373-84. [pmid: 2200321].
Eide TJ. Risk of colorectal cancer in adenoma-bearing individuals within a defined population. Int J Cancer. 1985;38:173-6. [pmid: 3733258].
Eide TJ, Stalsberg H. Polyps of the large intestine in northern Norway. Cancer. 1978;42:2839-48. [pmid: 728878].
Ekbom A, Helmick C, Zack M, Adami HO. Ulcerative colitis and colorectal cancer. A population-based study. N Engl J Med. 1990;323:1228-33. [pmid: 2215606].
Evers K, Laufer I, Gordon RL, et al. Double contrast enema examination for detection of rectal carcinoma. Radiology. 1981;140:635-9. [pmid: 7280227].
Fantini G, DeCosse J. Surveillance strategies after resection of carcinoma of the colon and rectum. Surg Gynecol Obstet. 1990;171:267-73. [pmid: 2201097].
Farrands P, Vellacott KD, Amar SS, et al. Flexible fiberoptic sigmoidoscopy and double-contrast barium-enema examination in the identification of adenomas and carcinoma of the colon. Dis Colon Rectum. 1983;26:725-7. [pmid: 6628146].
Fleisher M, Winawer SJ, Zauber AG, et al. Accuracy of fecal occult blood test interpretation. Ann Intern Med. 1991;114:875-6. [pmid: 2014949].
Fork FT. Double contrast enema and colonoscopy in polyp detection. Gut. 1981;22:971-7. [pmid: 7308852]. [pmcid: 1419466].
Foutch PG, Mai H, Pardy K, et al. Flexible sigmoidoscopy may be ineffective for secondary prevention of colorectal cancer in asymptomatic, average-risk men. Dig Dis Sci. 1991;36:924-8. [pmid: 2070706].
Frank-Stromborg M, Olsen SJ. Cancer prevention in minority populations. Cultural implications for health care professionals. St. Louis: Mosby. 1993.
Frazier AL, based on data from: Arminski TC, McLean DW. Incidence and distribution of adenomatous polyps of the colon and rectum based on 1,000 autopsy examinations. Dis Colon Rectum. 1964;7:249-61. [pmid: 14176135].
Frommer DJ, Kapparis A, Brown MK. Improved screening for colorectal cancer by immunological detection of occult blood. British Med J. 1988;296:1092-4.
Fuchs CS, Giovannucci EL, Colditz GA, et al. A prospective study of family history and risk of colorectal cancer. New Engl J Med. 1994;331:1669-74. [pmid: 7969357].
Gelfand DW, Ott DJ, Chen YM. Decreasing numbers of gastrointestinal studies: Report of data from 69 radiologic practices. Amer J Roentgenol. 1987;148:1133-6. [pmid: 3495137].
Gillen CD, Walmsley RS, Prior P, et al. Ulcerative colitis and Crohn's disease: A comparison of colorectal cancer risk in extensive colitis. Gut. 1994;35:1590-92. [pmid: 7828978]. [pmcid: 1375617].
Gnauck R, Macrae FA, Fleisher M. How to perform the fecal occult blood test. Cancer. 1984;34:134-47.
Godreau CJ. Office-based colonoscopy in a family practice. Fam Pract Res J. 1992;12:313-20. [pmid: 1414436].
Granqvist S. Distribution of polyps in the large bowel in relation to age. A colonoscopic study. Scand J Gastroenterol. 1981;16:1025-31. [pmid: 7336129].
Greegor DH. Diagnosis of large bowel cancer in the asymptomatic patient. JAMA. 1967;201:943-5. [pmid: 6072632].
Greegor DH. Occult blood testing for detection of asymptomatic colon cancer. Cancer. 1971;28:131-4. [pmid: 5110619].
Greenberg E, Baron JA, Tosteson TD, et al. A clinical trial of antioxidant vitamins to prevent colorectal adenoma. N Engl J Med. 1994;331:141-7. [pmid: 8008027].
Greenstein AJ, Sachar DB, Smith H, et al. Cancer in universal and left-sided ulcerative colitis: Factors determining risk. Gastroenterology. 1979;77:290-4. [pmid: 447042].
Grobe JL, Kozarek RA, Sanowski RA. Flexible versus rigid sigmoidoscopy: A comparison using an inexpensive 35-cm flexible proctosigmoidoscope. Am J Gastroenterol. 1983;78:569-71. [pmid: 6613970].
Grossman S, Milos ML, Tekawa IS, Jewell NP. Colonoscopic screening of persons with suspected risk factors for colon cancer. II. Past history of colorectal neoplasms. Gastroenterology. 1989;96:299-306. [pmid: 2910754].
Gyde S. Screening for colorectal cancer in ulcerative colitis: Dubious benefits and high costs. Gut. 1990;31:1089-92. [pmid: 2083852]. [pmcid: 1378729].
Hakkinen I, Paasivuo R, Partanen P. Screening for colorectal tumours using an improved faecal occult blood test:Quantitative aspects. Gut. 1988;29:1194-7. [pmid: 3197992]. [pmcid: 1434344].
Hardcastle JD, Armitage NC, Chamberlain JO, et al. Fecal occult blood screening for colorectal cancer in the general population. Results of a controlled trial. Cancer. 1986;58:397-403. [pmid: 3719535].
Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348:1472-77. [pmid: 8942775].
Hardcastle JD, Thomas WM, Chamberlain J, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Results for first 107,349 subjects. Lancet. 1989 May 27;;1:1160-4. [pmid: 2566735].
Harris RP, O'Malley MS, Fletcher SW, Knight BP. Prompting physicians for preventive procedures: A five-year study of manual and computer reminders. Am J Prev Med. 1990;6:145-52. [pmid: 2397138].
Hawes R, Lehman HA, Hast J, et al. Training resident physicians in fiberoptic sigmoidoscopy. How many supervised examinations are required to achieve competence?. Am J Med. 1986;80:465-70. [pmid: 3953621].
Hilsabeck J. Experience with routine office sigmoidoscopy using the 60 cm flexible colonoscope in private practice. Dis Colon Rectum. 1983;26:314-8. [pmid: 6653290].
Hixson LJ, Fennerty MB, Sampliner RE, Garewal HS. Prospective blinded trial of the colonoscopic miss-rate of large colorectal polyps. Gastrointest Endosc. 1991;37:125-7. [pmid: 2032595].
Hixson LJ, Fennerty MB, Sampliner RE, et al. Two-year incidence of colon adenomas developing after tandem colonoscopy. Am J Gastroenterol. 1994;89:687-91. [pmid: 8172138].
Hixson LJ, Fennerty MB, Sampliner RE, et al. Prospective study of the frequency and size distribution of polyps missed by colonoscopy. J Natl Cancer Inst. 1990;82:1769-72. [pmid: 2231773].
Hoff G, Foertser A, Vatn MN, et al. Epidemiology of polyps in the rectum and colon. Recovery and evaluation of unresected polyps 2 years after detection. Scand J Gastroenterol. 1986;21:853-62. [pmid: 3775252].
Hoff G, Vatn MN. Epidemiology of polyps in the rectum and sigmoid colon: Endoscopic evaluation of size and localization of polyps. Scand J Gastroenterol. 1985;20:356-60. [pmid: 4001845].
Holt Jr WS. Factors affecting compliance with screening sigmoidoscopy. J Fam Pract. 1991;32:585-9. [pmid: 2040883].
Howard J, Hankey BF, Greenberg RS, et al. A collaborative study of differences in the survival rates of black patients and white patients with cancer. Cancer. 1992;69:2349-60. [pmid: 1562983].
Jaramillo E, Slezak P. Comparison between double-contrast barium enema and colonoscopy to investigate lower gastrointestinal bleeding. Gastrointest Radiol. 1992;17:81-3. [pmid: 1544563].
Jarvinen HJ. Time and type of prophylactic surgery for familial adenomatous coli. Ann Surg. 1985;202:93-7. [pmid: 4015216]. [pmcid: 1250843].
Jarvinen HJ, Mecklin J-P, Sistonen P. Screening reduces colorectal cancer rate in families with hereditary nonpolyposis colorectal cancer. Gastroenterology. 1995;108:1405-11. [pmid: 7729632].
Jass JR. Pathology of hereditary non-polyposis colorectal cancer. Anticancer Res. 1994;14:1631-34. [pmid: 7979198].
Jensen J, Kewenter J, Aszteély M, et al. Double contrast barium enema and flexible rectosigmoidoscopy: A reliable diagnostic combination for detection of colorectal neoplasm. Br J Surg. 1990;77:270-2. [pmid: 2322788].
Jentschura D, Raute M, Winter J, et al. Complications in endoscopy of the lower gastrointestinal tract. Therapy and prognosis. Surg Endosc. 1994;8:672-6. [pmid: 8059305].
Jones LA. Minorities and cancer. New York:Springer-Verlag Publishers. 1989.
Jonsson B, Ahsgren L, Andersson LO, et al. Colorectal cancer surveillance in patients with ulcerative colitis. Brit J Surg. 1994;81:689-91. [pmid: 8044548].
Jorgensen OD, Kronborg O, Fenger C. The Funen adenoma follow-up study. Incidence and death from colorectal carcinoma in an adenoma surveillance program. Scan J Gastroenterol. 1993;28:869-74.
Kalra L, Hamlyn A. Comparative evaluation of investigations for colorectal carcinoma in symptomatic patients. Postgrad Med J. 1988;64:666-8. [pmid: 3251216]. [pmcid: 2428986].
Katzka I, Brody RS, Morris E, Katz S. Assessment of colorectal cancer risk in patients with ulcerative colitis: Experience from a private practice. Gastroenterology. 1983;85:22-9. [pmid: 6852458].
Kelly RB, Shank JC. Adherence to flexible sigmoidoscopy in asymptomatic patients. Med Care. 1992;30:1029-42. [pmid: 1434956].
Kewenter J, Brevinge H, Engaras B, et al. Results of screening, rescreening, and follow-up in a prospective randomized study for detection of colorectal cancer by fecal occult blood testing. Results for 68,308 subjects. Scand J Gastroenterol. 1994;29:468-73. [pmid: 8036464].
Kewenter J, Brevinge H, Engaras B, et al. Follow-up after screening for colorectal neoplasms with fecal occult blood testing in a controlled trial. Dis Colon Rectum. 1994;37:115-9. [pmid: 8306829].
Kewenter J, Brevinge G, Engaras B, Haglind E. The yield of flexible sigmoidoscopy and double-contrast barium enema in the diagnosis of neoplasms of the large bowel in patients with a positive Hemoccult test. Endoscopy. 1995;27:159-63. [pmid: 7601048].
Koretz RL. Malignant polyps: Are they sheep in wolves' clothing?. Ann Intern Med. 1993;118:63-8. [pmid: 8416159].
Kozuka S, Nogaki M, Ozeki T, Masumori S. Premalignancy of the mucosal polyp in the large intestine: II. Estimation of the periods required for malignant transformation of mucosal polyps. Dis Colon Rectum. 1975;18:494-500. [pmid: 1181151].
Kronborg O, Fenger C, Olsen J, et al. Randomised study of screening for colorectal cancer with fecal occult blood test. Lancet. 1996;348:1467-71. [pmid: 8942774].
Kronborg O, Fenger C, Wonn J, et al. Causes of death during the first 5 years of a randomized trial of mass screening for colorectal cancer with fecal occult blood test. Scand J Gastroenterol. 1992;27:47-52. [pmid: 1736342].
Kronborg O, Fenger C. Prognostic evaluation of planned follow-up in patients with colorectal adenomas. An interim report. Int J Colorectal Dis. 1987;2:203-7. [pmid: 3694018].
Kurtz RC. Diagnostic approach to the symptomatic patient. In: Cohen AM, Winawer SJ, eds. Cancer of the colon, rectum, and anus pp. 371-5. New York: McGraw Hill. 1995.
Lang CA, Ransohoff DF. Fecal occult blood screening for colorectal cancer: Is mortality reduced by chance selection for screening colonoscopy?. JAMA. 1994;271:1011-3. [pmid: 8139058].
Lanspa SJ, Lynch HT, Smyrk TC, et al. Colorectal adenomas in the Lynch Syndromes. Gastroenterology. 1990;98:1117-22. [pmid: 2323504].
Lennard-Jones JE, Connell WR. Surveillance--inflammatory bowel disease. In: Cohen AM, Winawer SJ, eds. Cancer of the colon, rectum, and anus, pp. 350-70. New York: McGraw-Hill. 1995.
Lennard-Jones JE, Melville DM, Morson BC, et al. Precancer and cancer in extensive ulcerative colitis: Findings among 401 patients over 22 years. Gut. 1990;31:800-6. [pmid: 2370015]. [pmcid: 1378540].
Lieberman DA. Cost-effectiveness model for colon cancer screening. Gastroenterology. 1995;109:1781-90. [pmid: 7498642].
Lieberman DA, Smith FW. Screening for colon malignancy with colonoscopy. Am J Gastroenterol. 1991;86:946-51. [pmid: 1858758].
Lynch DAF, Lobo AJ, Sobala GM, et al. Failure of colonoscopic surveillance in ulcerative colitis. Gut. 1993;34:1075-80. [pmid: 8174957]. [pmcid: 1374357].
Lynch HT, Harris RE, Bardawil WA, et al. Management of hereditary site-specific colon cancer. Arch Surg. 1977;112:170-4. [pmid: 836152].
Macrae FA, St. John DJ. Relationship between patterns of bleeding and Hemoccult sensitivity in patients with colorectal cancers and adenomas. Gastroenterology. 1982;82:891-8. [pmid: 7060910].
Mandel JS, Bond JH, Church TR, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med 1993;328:1365-71. [Published erratum in N Engl J Med 1993;329:672].
Mandel JS, Church TR, Ederer F. Screening for colorectal cancer (letter). N Engl J Med. 1993;329:1353-4. [pmid: 8413423].
Manning AP, Bulgim OR, Dixon MF, Axon AT. Screening by colonoscopy for colonic epithelial dysplasia in inflammatory bowel disease. Gut. 1987;28:1489-94. [pmid: 3428676]. [pmcid: 1433679].
Marks G, Boggs HW, Castro AF, et al. Sigmoidoscopic examinations with rigid and flexible fiberoptic sigmoidoscopes in the surgeon's office. Dis Colon Rectum. 1979;22:162-9. [pmid: 446248].
Maule WF. Screening for colorectal cancer by nurse endoscopists. N Engl J Med. 1994;330:183-7. [pmid: 8264742].
Mayberry RM, Coates RJ, Hill HA, et al. Determinants of black/white differences in colon cancer survival. J Natl Cancer Inst. 1995;87:1686-93. [pmid: 7473817].
McAfee JH, Katon RM. Tiny snares prove safe and effective for removal of diminutive colorectal polyps. Gastro Endosc. 1994;40:301-3.
McCarthy BD, Moskowitz MA. Screening flexible sigmoidoscopy: Patient attitudes and compliance. J Gen Int Med. 1993;8:120-5.
Mecklin P, Jarvinen HJ, Peltokallio P. Cancer family syndrome. Genetic analysis of 22 Finnish kindreds. Gastroenterology. 1986;90:328-33. [pmid: 3940911].
Miller BA, Ries LA, Hankey BF, et al. Cancer statistics review: 1973-1990. Bethesda MD; National Cancer Institute; DHHS Publication No. (NIH) 92-2789. 1992.
Morris JB, Stellato TA, Guy BB, et al. A critical analysis of the largest reported mass fecal occult blood screening program in the United States. Am J Surg. 1991;161:101-5. [pmid: 1987842].
Morson BC. The evolution of colorectal carcinoma. Clin Radiology. 1984;35:425-31.
Muller AD, Sonnenberg A. Protection by endoscopy against death from colorectal cancer. Arch Intern Med. 1995a;;155:1741-8. [pmid: 7654107].
Muller AD, Sonnenberg A. Prevention of colorectal cancer by flexible endoscopy and polypectomy. A case-control study of 32,702 veterans. Ann Intern Med. 1995b;;123:904-10. [pmid: 7486484].
Muto T, Bussey HJR, Morson BC. The evolution of cancer of the colon and rectum. Cancer. 1975;36:2251-70. [pmid: 1203876].
Myers RE, Trock BJ, Lerman C, et al. Adherence to colorectal cancer screening in an HMO population. Prev Med. 1990;19:502-14. [pmid: 2235919].
Myers RE, Balshem AM, Wolf TA, et al. Adherence to continuous screening for colorectal neoplasia. Med Care. 1993;31:508-19. [pmid: 8501998].
Myers RE, Ross EA, Wolf TA, et al. Behavioral interventions to increase adherence in colorectal cancer screening. Med Care. 1991;29:1039-50. [pmid: 1921523].
National Cancer Institute: Cancer statistics review. 1973-1987. Bethesda, MD; NCI Publication No. (NIH) 90-2789. 1990.
Nava H, Pagana T. Postoperative surveillance of colorectal carcinoma. Cancer. 1982;49:1043-7. [pmid: 7059921].
Neale AV, Deiners RY, Hennan S. Compliance with colorectal cancer screening in a high-risk occupational group. J Occup Med. 1989;31:1007-12. [pmid: 2614532].
Nelson RL. Iatrogenic perforation of the colon and rectum. Dis Colon Rectum. 1982;25:305-8. [pmid: 7083975].
Newcomb PA, Norfleet RG, Storer BE, et al. Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. 1992;84:1572-5. [pmid: 1404450].
Norfleet RG. Effect of diet on fecal occult blood testing in patients with colorectal polyps. Dig Dis Sci. 1986;31:498-501. [pmid: 3009111].
Norfleet R, Ryan ME, Wyman JB, et al. Barium enema versus colonoscopy for patients with polyps found during flexible sigmoidoscopy. Gastrointest Endosc. 1991;37:531-4. [pmid: 1936830].
O'Brien MJ, Winawer SJ, Zauber AG, et al. The National Polyp Study. Patient and polyp characteristics associated with high-grade dysplasia in colorectal adenomas. Gastroenterology. 1990;98:371-9. [pmid: 2403953].
Petravage J, Swedberg J. Patient response to sigmoidoscopy recommendations via mailed reminders. J Fam Pract. 1988;27:387-9. [pmid: 3171490].
Polednak AP. Knowledge of colorectal cancer and use of screening tests among higher risk persons. J Cancer Educ. 1990;5:115-24. [pmid: 2206933].
Portes C, Majarakis JD. Proctosigmoidoscopy:Incidence of polyps in 50,000 examinations. JAMA. 1957;163:411-3.
Potter JD, Slattery ML, Bostick RM, Gapstur SM. Colon cancer: A review of the epidemiology. Epidemiol Reviews. 1993;15:499-545.
Protell RL, Buenger N, Gilbert DA, et al. The short colonoscope: Preliminary analysis of a comparison with rigid sigmoidoscopy and Hemoccult testing. Gastrointest Endosc. 1978;24.
Provenzale D, Kowdley KV, Arora S, Wong JB. Prophylactic colectomy or surveillance for chronic ulcerative colitis? A decision analysis. Gastroenterology. 1995;109:1188-96. [pmid: 7557085].
Ransohoff DF, Lang CA. Small adenomas detected during fecal occult blood test screening for colorectal cancer. The impact of serendipity. JAMA. 1990;264:76-8. [pmid: 2192093].
Read TE, Read JD, Butterfly, LF. Importance of adenomas 5 mm or less in diameter that are detected by sigmoidoscopy. N Engl J Med. 1997;336:8-12. [pmid: 8970934].
Reilly J, Rusin L, Theuerkauf F. Colonoscopy: Its role in cancer of the colon and rectum. Dis Colon Rectum. 1982;25:532-8. [pmid: 7117057].
Report of the U.S. Preventive Services Task Force. Guide to clinical preventive services. Baltimore: Williams and Wilkins. 1989.
Report of the U.S. Preventive Services Task Force. Guide to clinical preventive services. Baltimore: Williams and Wilkins. 1996.
Rex DK, Lehman GA, Hawes RH, et al. Screening colonoscopy in asymptomatic average-risk persons with negative fecal occult blood tests. Gastroenterology. 1991;100:64-7. [pmid: 1796931].
Rex DK, Lehman GA, Ulbright TM, et al. Colonic neoplasia in asymptomatic persons with negative fecal occult blood tests:Influence of age, gender, and family history. Am J Gastroenterol. 1993;88:825-31. [pmid: 8503374].
Rex DK, Weddle RA, Lehman GA, et al. Flexible sigmoidoscopy plus air contrast barium enema versus colonoscopy for suspected lower gastrointestinal bleeding. Gastroenterology. 1990;98:855-61. [pmid: 2107112].
Rickert RR, Auerbach O, Garfinkel L, et al. Adenomatous lesions of the large bowel: An autopsy survey. Cancer. 1979;43:1847-57. [pmid: 445371].
Rodney LM, Randolph J, Peterson D. Cancellation rates and gas scores for air contrast barium enema immediately after 65-cm flexible sigmoidoscopy. A randomized clinical trial. J Clin Gastroenterol. 1988;10:311-4. [pmid: 2980767].
Rodney LM, Albers G. Flexible sigmoidoscopy: Primary care outcomes after two types of continuing medical education. Am J Gastroenterology. 1986;83:133-7.
Rogge JD, Elmore MF, Mahoney SJ, et al. Low-cost, office-based, screening colonoscopy. Am J Gastroenterol. 1994;89:1775-80. [pmid: 7942665].
Rosen L, Bub DS, Reed JF, Nastasee SA. Hemorrhage following colonoscopic polypectomy. Dis Colon Rectum. 1993;36:1126-31. [pmid: 8253009].
Rosevelt J, Frankl H. Colorectal cancer screening by nurse practitioners using 60-cm flexible fiberoptic sigmoidoscope. Dig Dis Sci. 1984;29:161-3. [pmid: 6607823].
Rustgi AK. Hereditary gastrointestinal polyposis and nonpolyposis syndromes. New Engl J Med. 1994;331:1694-702. [pmid: 7969362].
Saito Y, Slezak P, Rubio C. The diagnostic value of combining flexible sigmoidoscopy and double-contrast barium enema as a one-stage procedure. Gastrointest Radiol. 1989;14:357-9. [pmid: 2806824].
Schrock TR. Conceptual developments through colonoscopy. Surg Endosc. 1988;2:240-4. [pmid: 3242146].
Schrock TR. Colonoscopy versus barium enema in the diagnosis of colorectal cancer and polyps. Gastrointestinal Endoscopy Clin of North Amer. 1993;3:585-610.
Selby JV, Friedman GD. US Preventive Services Task Force. Sigmoidoscopy in the periodic health examination of asymptomatic adults. JAMA. 1989;261:594-601. [pmid: 2642564].
Selby JV, Friedman GD, Collen MF. Sigmoidoscopy and mortality from colorectal cancer: The Kaiser Permanente Multiphasic Evaluation Study. J Clin Epidemiol. 1988;41:427-34. [pmid: 3367172].
Selby JV, Friedman GD, Quesenberry Jr CP, Weiss NS. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326:653-7. [pmid: 1736103].
Selby JV, Friedman GD, Quesenberry Jr CP, Weiss NS. Effect of fecal occult blood testing on mortality from colorectal cancer. A case-control study. Ann Intern Med. 1993;118:1-6. [pmid: 8416152].
Shapiro M. Colorectal cancer screening by paramedical personnel. Dig Dis Sci. 1984;29:159-60. [pmid: 6421553].
Spencer RJ, Melton III LJ, Ready RL, Ilstrup DM. Treatment of small colorectal polyps: A population-based study of the risk of subsequent carcinoma. Mayo Clin Proc. 1984;59:305-10. [pmid: 6727422].
St. John DJ, Young GP, Alexeyeff MA, et al. Evaluation of new occult blood tests for detection of colorectal neoplasia. Gastroenterology. 1993;104:1661-8. [pmid: 8500724].
St. John DJ, Young GP, McHutchison JG, et al. Comparison of the specificity and sensitivity of Hemoccult and Hemoquant in screening for colorectal neoplasia. Ann Intern Med. 1992;117:367-82. [pmid: 1503328].
St. John DJ, McDermott FT, Hopper JL, et al. Cancer risk in relatives of patients with common colorectal cancer. Ann Intern Med. 1993;118:785-90. [pmid: 8470852].
Stein S. Which hurts the most? A comparison of pain rating during double-contrast barium enema examination and colonoscopy. Radiology. 1994;191:99-101. [pmid: 8134605].
Stein S, Stordahl A, Lunde OC, et al. Double-contrast barium enema versus colonoscopy in the diagnosis of neoplastic disorders: Aspects of decision-making in general practice. Fam Pract. 1993;10:288-91. [pmid: 8282153].
Stephenson BM, Murday VA, Finan PJ, et al. Feasibility of family-based screening for colorectal neoplasia: Experience in one general surgical practice. Gut. 1993;34:96-100. [pmid: 8432460]. [pmcid: 1374108].
Struewing JP, Pape DM, Snow DA. Improving colorectal cancer screening in a medical residents' primary care clinic. Am J Prev Med. 1991;7:75-81. [pmid: 1910891].
Stryker SJ, Wolff BG, Culp CE, et al. Natural history of untreated colonic polyps. Gastroenterology. 1987;93:1009-13. [pmid: 3653628].
Tate J, Royle G. Open access colonoscopy for suspected colonic neoplasia. Gut. 1988;29:1322-5. [pmid: 3197977]. [pmcid: 1433991].
Thoeni R, Menuck L. Comparison of barium enema and colonoscopy in the detection of small colonic polyps. Radiology. 1977;124:631-5. [pmid: 887751].
Tierney WM, Hui SL, McDonald CJ. Delayed feedback of physician performance versus immediate reminders to perform preventive care: Effects on physician compliance. Med Care. 1986;24:659-66. [pmid: 3736141].
Todd G, Forde K. Lower gastrointestinal bleeding with negative or inconclusive radiographic studies: The role of colonoscopy. Am J Surg. 1979;138:627-8. [pmid: 315170].
Tripp MR, Morgan TR, Sampliner RE, et al. Synchronous neoplasms in patients with diminutive colorectal adenomas. Cancer. 1987;60:1599-603. [pmid: 3621130].
Van Ness MM, Chobanian SJ, Winters Jr C, et al. A study of patient acceptance of double-contrast barium enema and colonoscopy. Which procedure is preferred by patients?Arch Intern Med. 1987;147:2175-6.
Vasen HFA, Mecklin JP, Kahn PM, et al. The International Collaborative Group on Hereditary Non-Polyposis Colon Cancer (ICG-HNPCC). Dis Colon Rectum. 1991;34:424-5. [pmid: 2022152].
Vasen HFA, Nagengast FM, Khan PM. Interval cancers in hereditary non-polyposis colorectal cancer (Lynch syndrome). Lancet. 1995;345:1183-4. [pmid: 7723574].
Vatn MH, Stalsbert H. The prevalence of polyps of the large intestine in Oslo: An autopsy study. Cancer. 1982;49:819-25. [pmid: 7055790].
Vernon SW. Adherence to colorectal cancer screening. A brief overview. Ann NY Acad Sci. 1995;768:292-5. [pmid: 8526370].
Wagner JL, Tunis S, Brown M, et al. Cost-effectiveness of colorectal cancer screening in average-risk adults. In: G. Young and B. Levin, eds., Prevention and early detection of colorectal cancer. London: WB Saunders.1996.
Warneke J, Petrelli N, Herrera L, Nava H. Accuracy of colonoscopy for the detection of colorectal polyps. Dis Colon Rectum. 1992;35:981-5. [pmid: 1395987].
Waye JD, Lewis BS, Frankel A, Geller SA. Small colon polyps. Am J Gastroenterol. 1988;83:120-2. [pmid: 3341333].
Waye JD, Lewis BS, Yessayan S. Colonoscopy: A prospective report of complications. J Clin Gastroenterol. 1992;15:347-51. [pmid: 1294644].
Weinrich SP, Weinrich MC, Boyd MD, et al. Knowledge of colorectal cancer among older persons. Cancer Nursing. 1992;15:322-30. [pmid: 1423251].
Williams AR, Balasooriya BAW, Day DW. Polyps and cancer of the large bowel: A necropsy study in Liverpool. Gut. 1982;l23:835-42. [pmid: 7117903]. [pmcid: 1419830].
Williams CB, Hunt R, Loose H, et al. Colonoscopy in the management of colon polyps. Br J Surg. 1974;61:673-4. [pmid: 4606357].
Williams CB, Macrae FA, Bartram C. A prospective study of diagnostic methods in adenoma follow-up. Endoscopy. 1982;14:74-8. [pmid: 7075563].
Williams AR, Hunter R, Thomas DW, et al. Evaluation of immunochemical test for fecal occult blood in screening for colorectal neoplasia in a high risk group. Aust NZ J Surg. 1987;57:951-7.
Winawer SJ. Surveillance overview. In: Cohen AM, Winawer SJ, eds. Cancer of the colon, rectum, and anus, p. 265. New York:McGraw Hill. 1995.
Winawer SJ, Bond JH. Fecal occult blood test screening trials. In: Cohen AM, Winawer SJ, eds. Cancer of the colon, rectum, and anus, pp. 279-90. New York: McGraw-Hill. 1995.
Winawer SJ, Flehinger BJ, Schottenfeld D, Miller DG. Screening for colorectal cancer with fecal occult blood testing and sigmoidoscopy. J Natl Cancer Inst. 1993;85:1311-8. [pmid: 8340943].
Winawer SJ, Leidner SD, Boyle C, Kurtz RC. Comparison of flexible sigmoidoscopy with other diagnostic techniques in the diagnosis of rectocolon neoplasia. Dig Dis Sci. 1979;24:277-81. [pmid: 456214].
Winawer SJ, Miller C, Lightdale CI, et al. Patient response to sigmoidoscopy: A randomized controlled trial of rigid and flexible sigmoidoscopy. Cancer. 1987;60:1905-8. [pmid: 3308058].
Winawer SJ, Zauber AG, Diaz B. The National Polyp Study: Temporal sequence of evolving colorectal cancer from the normal colon. Gastrointest Endosc. 1987;33.
Winawer SJ, Zauber AG, Gerdes H, et al. Risk of colorectal cancer in the families of patients with adenomatous polyps. New Engl J Med. 1996;334:82-7. [pmid: 8531963].
Winawer SJ, Zauber AG, Ho MN, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329:1977-81. [pmid: 8247072].
Winawer SJ, Zauber AG, O'Brien MJ, et al. The National Polyp Study. 1. Design, methods, and characteristics of patients with newly diagnosed polyps. The National Polyp Study Workgroup. Cancer. 1992;70(5 Suppl):1236-45. [pmid: 1511370].
Winawer SJ, Zauber AG, O'Brien MJ, et al. Randomized comparison of surveillance intervals after colonoscopic removal of newly diagnosed adenomatous polyps. N Engl J Med. 1993;328:901-6. [pmid: 8446136].
Wingo PA, Tong T, Bolden S. Cancer statistics 1995. Cancer. 1995;45:8-30. [pmid: 8625085].
Winnan G, Berci G, Panish J, et al. Superiority of the flexible to the rigid sigmoidoscope in routine proctosigmoidoscopy. N Engl J Med. 1980;302:1011-2. [pmid: 7366608].
Young GP, St. John JB. Selecting an occult blood test for use as a screening tool for large bowel cancer. Front Gastrointest Res. 1991;18:135-56.
Zapka JG, Palmer RH, Hargraves JL. Relationship of patient satisfaction with experienced systems performance and health status. J Ambul Care Man. 1995;18:73-83.
Zarchy TM, Ershoff D. Do characteristics of adenomas on flexible sigmoidoscopy predict advanced lesions on baseline colonoscopy?. Gastroenterology. 1994;106:1501-4. [pmid: 8194695].
Zucker GM, Madura MJ, Chmiel JS, Olinger EJ. The advantages of the 30-cm flexible sigmoidoscope over the 60-cm flexible sigmoidoscope. Gastrointest Endosc. 1984;30:59-64. [pmid: 6714601].