# References

Ahlquist DA, Wieand HS, Moertel CG, et al. Accuracy of fecal occult blood screening for colorectal neoplasia. A prospective study using Hemoccult and HemoQuant tests. JAMA. 1993;269:1262-7. [pmid: 8437303].
Allison JE, Tekawa IS, Ransom LJ, Adrian AL. A comparison of fecal occult-blood tests for colorectal cancer screening. N Engl J Med. 1996;334:155-9. [pmid: 8531970].
American Cancer Society. Cancer facts and figures, 1996. Atlanta, GA: American Cancer Society; Publication No. 5008-96. 1996.
Anderson LM, Heigh RI, McCoy GA, et al. Accuracy of assessment of the extent of examination by experienced colonoscopists. Gastrointest Endosc. 1992;38:560-3. [pmid: 1397910].
Anderson LM, May DS. Has the use of cervical, breast and colorectal cancer screening increased in the United States?. Am J Public Health. 1995;85:840-2. [pmid: 7762721]. [pmcid: 1615482].
Atkin WS, Morson BC, Cuzick J. Long-term risk of colorectal cancer after excision of rectosigmoid adenomas. N Engl J Med. 1992;326:658-62. [pmid: 1736104].
Baille J, Ravich WJ. On endoscopic training and procedural competence. Ann Intern Med. 1993;118:73-4. [pmid: 8416163].
Baquet CR, Hunter CP. Patterns of minorities and special populations. In: Greenwald P, Kramer BS, Weed DL, eds. Cancer prevention and control. New York: Dekker, 1995.
Bernstein MA, Feczko PJ, Halpert RD, et al. Distribution of colonic polyps: Increased incidence of proximal lesions in older patients. Radiology. 1985;155:35-8. [pmid: 3975415].
Blalock SJ, DeVellis BM, Sandler RS. Participation in fecal occult blood screening:A critical review. Prev Med. 1987;16:9-18. [pmid: 3547387].
Blatt LJ. Polyps of the colon and rectum:Incidence and distribution. Dis Colon Rectum 1961; 4: 277-82.
Bloomfield JA. Reliability of barium enema in detecting colonic neoplasia. Med J Austr 1981;1631-3.
Bolt RJ. Sigmoidoscopy in detection and diagnosis in the asymptomatic individual. Cancer. 1971;28:121-2. [pmid: 5110616].
Bostick RM, Sprafka JM, Virning BA, Potter JD. Knowledge, attitudes and personal practices regarding prevention and early detection of cancer. Prev Med. 1993;22:65-85. [pmid: 8475013].
Brewster NT, Grieve DC, Saunders JH. Double-contrast barium enema and flexible sigmoidoscopy for routine colonic investigation. Brit J Surg. 1994;8:445-7.
Brown ML, Potosky AL, Thompson GB, Kessler LG. The knowledge and use of screening tests for colorectal and prostate cancer: Data from the 1987 National Health Interview Survey. Prev Med. 1990;19:562-74. [pmid: 2235923].
Burt RW, Bishop DT, Lynch HT, et al. Risk and surveillance of individuals with heritable factors for colorectal cancer. Bull WHO. 1990;68:655-65. [pmid: 2289301].
Byrd RL, Boggs HW Jr, Slagle GW, Cole PA. Reliability of colonoscopy. Dis Colon Rectum. 1989;32:1023-5. [pmid: 2591276].
Cass OW, Freeman ML, Peine CJ, et al. Objective evaluation of endoscopy skills during training. Ann Intern Med. 1993;118:40-3. [pmid: 8416157].
Centers for Disease Control and Prevention. Screening for colorectal cancer-United States,1992-1993, and new guidelines. MMWR. 1996;45:107-10. [pmid: 8592492].
Cordis JWV Jr, Johnson H Jr. Anatomic distribution of colonic cancers in middle-class black Americans. J Natl Med Assoc. 1991;83:730-2. [pmid: 1956086]. [pmcid: 2627127].
Durdey P, Weston PMT, Williams NS. Colonoscopy or barium enema as initial investigation of colonic disease. Lancet. 1987;5:549-51. [pmid: 2890043].
Eide TJ. Risk of colorectal cancer in adenoma-bearing individuals within a defined population. Int J Cancer. 1985;38:173-6. [pmid: 3733258].
Eide TJ, Stalsberg H. Polyps of the large intestine in northern Norway. Cancer. 1978;42:2839-48. [pmid: 728878].
Ekbom A, Helmick C, Zack M, Adami HO. Ulcerative colitis and colorectal cancer. A population-based study. N Engl J Med. 1990;323:1228-33. [pmid: 2215606].
Fork FT. Double contrast enema and colonoscopy in polyp detection. Gut. 1981;22:971-7. [pmid: 7308852]. [pmcid: 1419466].
Foutch PG, Mai H, Pardy K, et al. Flexible sigmoidoscopy may be ineffective for secondary prevention of colorectal cancer in asymptomatic, average-risk men. Dig Dis Sci. 1991;36:924-8. [pmid: 2070706].
Fuchs CS, Giovannucci EL, Colditz GA, et al. A prospective study of family history and risk of colorectal cancer. N Engl J Med. 1994;331:1669-74. [pmid: 7969357].
Gillen CD, Walmsley RS, Prior P, et al. Ulcerative colitis and Crohn's disease: A comparison of colorectal cancer risk in extensive colitis. Gut. 1994;35:1590-2. [pmid: 7828978]. [pmcid: 1375617].
Godreau CJ. Office-based colonoscopy in a family practice. Fam Pract Res J. 1992;12:313-20. [pmid: 1414436].
Granqvist S. Distribution of polyps in the large bowel in relation to age. A colonoscopy study. Scand J Gastroenterol. 1981;16:1025-31. [pmid: 7336129].
Greegor DH. Diagnosis of large bowel cancer in the asymptomatic patient. JAMA. 1967;201:943-5. [pmid: 6072632].
Greegor DH. Occult blood testing for detection of asymptomatic colon cancer. Cancer. 1971;28:131-4. [pmid: 5110619].
Greenstein AJ, Sachar DB, Smith H, et al. Cancer in universal and left-sided ulcerative colitis: Factors determining risk. Gastroenterology. 1979;77:290-4. [pmid: 447042].
Grossman S, Milos ML, Tekawa IS, Jewell NP. Colonoscopic screening of persons with suspected risk factors for colon cancer: II. Past history of colorectal neoplasms. Gastroenterology. 1989;96:299-306. [pmid: 2910754].
Hardcastle JD, Armitage NC, Chamberlain J, et al. Fecal occult blood screening for colorectal cancer in the general population. Results of a controlled trial. Cancer. 1986;58:397-403. [pmid: 3719535].
Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348:1472-7. [pmid: 8942775].
Hixson LJ, Fennerty MB, Sampliner RE, et al. Prospective study of the frequency and size distribution of polyps missed by colonoscopy. J Natl Cancer Inst. 1990;82:1769-72. [pmid: 2231773].
Hixson LJ, Fennerty MB, Sampliner RE, et al. Prospective blinded trial of the colonoscopic miss-rate of large colorectal polyps. Gastrointest Endosc. 1991;37:125-7. [pmid: 2032595].
Hoff G, Foertser A, Vatn MN, et al. Epidemiology of polyps in the rectum and colon. Recovery and evaluation of unresected polyps 2 years after detection. Scand J Gastroenterol. 1986;21:853-62. [pmid: 3775252].
Holt WS Jr. Factors affecting compliance with screening sigmoidoscopy. J Fam Pract. 1991;32:585-9. [pmid: 2040883].
Howard J, Hankey BF, Greenberg RS, et al. A collaborative study of differences in the survival rates of black patients and white patients with cancer. Cancer. 1992;69:2349-60. [pmid: 1562983].
Jaramillo E, Slezak P. Comparison between double-contrast barium enema and colonoscopy to investigate lower gastrointestinal bleeding. Gastrointest Radiol. 1992;17:81-3. [pmid: 1544563].
Jarvinen HJ. Time and type of prophylactic surgery for familial adenomatous coli. Ann Surg. 1985;202:93-7. [pmid: 4015216]. [pmcid: 1250843].
Jass JR. Pathology of hereditary non-polyposis colorectal cancer. Anticancer Res. 1994;14:1631-4. [pmid: 7979198].
Jensen J, Kewenter J, Aszteély M, et al. Double contrast barium enema and flexible rectosigmoidoscopy: A reliable diagnostic combination for detection of colorectal neoplasm. Br J Surg. 1990;77:270-2. [pmid: 2322788].
Jentschura D, Raute M, Winter J, et al. Complications of endoscopy of the lower gastrointestinal tract. Therapy and prognosis. Surg Endosc. 1994;8:672-6. [pmid: 8059305].
Jorgensen OD, Kronborg O, Fenger C. The Funen adenoma follow-up study. Incidence and death from colorectal carcinoma in an adenoma surveillance program. Scan J Gastroenterol. 1993;28:869-74.
Kalra L, Hamlyn A. Comparative evaluation of investigations for colorectal carcinoma in symptomatic patients. Postgrad Med J. 1988;64:666-8. [pmid: 3251216]. [pmcid: 2428986].
Katzka I, Brody RS, Morris E, and Katz S. Assessment of colorectal cancer risk in patients with ulcerative colitis: experience from a private practice. Gastroenterology. 1983;85:22-9. [pmid: 6852458].
Kelly RB, Shank JC. Adherence to flexible sigmoidoscopy in asymptomatic patients. Med Care. 1992;30:1029-42. [pmid: 1434956].
Kewenter J, Brevinge H, Engaras B, et al. Results of screening, rescreening, and follow-up in a prospective randomized study for detection of colorectal cancer by fecal occult blood testing. Results for 68,308 subjects. Scand J Gastroenterol. 1994;29:468-73. [pmid: 8036464].
Kewenter J, Brevinge G, Engaras B, and Haglind E. The yield of flexible sigmoidoscopy and double-contrast barium enema in the diagnosis of neoplasms of the large bowel in patients with a positive Hemoccult test. Endoscopy. 1995;27:159-163. [pmid: 7601048].
Kronborg O, Fenger, C. Prognostic evaluation of planned follow-up in patients with colorectal adenomas. An interim report. Int J Colorectal Dis. 1987;2:203-7. [pmid: 3694018].
Kronborg O, Fenger C, Olsen J, et al. Randomised study of screening for colorectal cancer with faecal-occult-blood test. Lancet. 1996;348:1467-71. [pmid: 8942774].
Kronborg O, Fenger C, Wonn J, et al. Causes of death during the first 5 years of a randomized trial of mass screening for colorectal cancer with fecal occult blood test. Scand J Gastroenterol. 1992;27:47-52. [pmid: 1736342].
Lang CA, Ransohoff DF. Fecal occult blood screening for colorectal cancer: Is mortality reduced by chance selection for screening colonoscopy?. JAMA. 1994;271:1011-3. [pmid: 8139058].
Lennard-Jones JE, Connell WR. Surveillance - inflammatory bowel disease. In: Cohen AM, Winawer SJ eds. Cancer of the colon, rectum, and anus. New York: McGraw-Hill, 1995:350-70.
Lennard-Jones JE, Melville DM, Morson BC, et al. Precancer and cancer in extensive ulcerative colitis: Findings among 401 patients over 22 years. Gut. 1990;31:800-6. [pmid: 2370015]. [pmcid: 1378540].
Lieberman DA. Cost-effectiveness model for colon cancer screening. Gastroenterology. 1995;109:1781-90. [pmid: 7498642].
Lieberman DA, Smith FW. Screening for colon malignancy with colonoscopy. Am J Gastroenterol. 1991;86:946-51. [pmid: 1858758].
Macrae FA, St. John DJ. Relationship between patterns of bleeding and Hemoccult sensitivity in patients with colorectal cancers and adenomas. Gastroenterology. 1982;82:891-8. [pmid: 7060910].
Mandel JS, Bond JH, Church TR, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med 1993;328:1365-71. [Published erratum appears in N Engl J Med 1993;329:672]
Mandel JS, Church TR, Ederer F. Screening for colorectal cancer (letter). N Engl J Med. 1993;329:1353-4. [pmid: 8413423].
Mayberry RM, Coates RJ, Hill HA, et al. Determinants of black/white differences in colon cancer survival. J Natl Cancer Inst. 1995;87:1686-93. [pmid: 7473817].
McAfee JH, Katon RM. Tiny snares prove safe and effective for removal of diminutive colorectal polyps. Gastrointest Endosc. 1994;40:301-3. [pmid: 8056232].
McCarthy BD, Moskowitz MA. Screening flexible sigmoidoscopy: Patient attitudes and compliance. J Gen Intern Med. 1993;8:120-5. [pmid: 8455106].
Miller BA, Ries LA, Hankey BF, et al. Cancer statistics review: 1973-1990. Bethesda MD:National Cancer Institute. DHHS Publication No. (NIH) 92-2789.
Morson BC. The evolution of colorectal carcinoma. Clin Radiol. 1984;35:425-31. [pmid: 6499378].
Muller AD, Sonnenberg A. Protection by endoscopy against death from colorectal cancer. Arch Intern Med. 1995a;;155:1741-8. [pmid: 7654107].
Muller AD, Sonnenberg A. Prevention of colorectal cancer by flexible endoscopy and polypectomy. A case-control study of 32,702 veterans. Ann Intern Med. 1995b;;123:904-10. [pmid: 7486484].
Myers RE, Trock BJ, Lerman C, et al. Adherence to colorectal cancer screening in an HMO population. Prev Med. 1990;19:502-14. [pmid: 2235919].
National Cancer Institute: Cancer statistics review 1973-1987. Bethesda, MD; NCI Publication No. (NIH) 90-2789. 1990.
Nelson RL. Iatrogenic perforation of the colon and rectum. Dis Colon Rectum. 1982;25:305-8. [pmid: 7083975].
Newcomb PA, Norfleet RG, Storer BE, et al. Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. 1992;84:1572-5. [pmid: 1404450].
O'Brien MJ, Winawer SJ, Zauber AG, et al. The National Polyp Study. Patient and polyp characteristics associated with high-grade dysplasia in colorectal adenomas. Gastroenterology. 1990;98:371-9. [pmid: 2403953].
Portes C, Majarakis JD. Proctosigmoidoscopy: Incidence of polyps in 50,000 examinations. JAMA. 1957;163:411-3.
Provenzale D, Kowdley KV, Arora S, and Wong JB. Prophylactic colectomy or surveillance for chronic ulcerative colitis? A decision analysis. Gastroenterology. 1995;109:1188-96. [pmid: 7557085].
Read TE, Read JD, Butterfly, LF. Importance of adenomas 5 mm or less in diameter that are detected by sigmoidoscopy. N Engl J Med. 1997;336:8-12. [pmid: 8970934].
Rex DK, Lehman GA, Hawes RH, et al. Screening colonoscopy in asymptomatic average-risk persons with negative fecal occult blood tests. Gastroenterology. 1991;100:64-7. [pmid: 1796931].
Rex DK, Lehman GA, Ulbright TM, et al. Colonic neoplasia in asymptomatic persons with negative fecal occult blood tests:Influence of age, gender, and family history. Am J Gastroenterol. 1993;88:825-31. [pmid: 8503374].
Rex DK, Weddle RA, Lehman GA, et al. Flexible sigmoidoscopy plus air contrast barium enema versus colonoscopy for suspected lower gastrointestinal bleeding. Gastroenterology. 1990;98:855-61. [pmid: 2107112].
Rickert RR, Auerbach O, Garfinkel L, et al. Adenomatous lesions of the large bowel: An autopsy survey. Cancer. 1979;43:1847-57. [pmid: 445371].
Rogge JD, Elmore MF, Mahoney SJ, et al. Low-cost, office-based, screening colonoscopy. Am J Gastroenterol. 1994;89:1775-80. [pmid: 7942665].
Rosen L, Bub DS, Reed JF, Nastasee SA. Hemorrhage following polypectomy. Dis Colon Rectum. 1993;36:1126-31. [pmid: 8253009].
Selby JV, Friedman GD. US Preventive Services Task Force. Sigmoidoscopy in the periodic health examination of asymptomatic adults. JAMA. 1989;261:594-601. [pmid: 2642564].
Selby JV, Friedman GD, Collen MF. Sigmoidoscopy and mortality from colorectal cancer: The Kaiser Permanente Multiphasic Evaluation Study. J Clin Epidemiol. 1988;41:427-34. [pmid: 3367172].
Selby JV, Friedman GD, Quesenberry CP Jr, Weiss NS. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326:653-7. [pmid: 1736103].
Selby JV, Friedman GD, Quesenberry CP Jr, Weiss NS. Effects of fecal occult blood testing on mortality from colorectal cancer. A case-control study. Ann Intern Med. 1993;118:1-6. [pmid: 8416152].
Spencer RJ, Melton LJ III, Ready RL, Ilstrup DM. Treatment of small colorectal polyps: A population-based study of the risk of subsequent carcinoma. Mayo Clin Proc. 1984;59:305-10. [pmid: 6727422].
St. John DJ, Young GP, McHutchison JG, et al. Comparison of the specificity and sensitivity of Hemoccult and Hemoquant in screening for colorectal neoplasia. Ann Intern Med. 1992;117:367-82. [pmid: 1503328].
St. John DJ, Young GP, Alexeyeff MA, et al. Evaluation of new occult blood tests for detection of colorectal neoplasia. Gastroenterology. 1993;104:1661-8. [pmid: 8500724].
Stein S. Which hurts the most? A comparison of pain rating during double-contrast barium enema examination and colonoscopy. Radiology. 1994;191:99-101. [pmid: 8134605].
Steine S, Stordahl A, Lunde OC, et al. Double-contrast barium enema versus colonoscopy in the diagnosis of neoplastic disorders: Aspects of decision making in general practice. Fam Pract. 1993;10:288-91. [pmid: 8282153].
Stephenson BM, Murday VA, Finan PJ, et al. Feasibility of family-based screening for colorectal neoplasia: Experience in one general surgical practice. Gut. 1993;34:96-100. [pmid: 8432460]. [pmcid: 1374108].
Tripp MR, Morgan TR, Sampliner RE, et al. Synchronous neoplasms in patients with diminutive colorectal adenomas. Cancer. 1987;60:1599-603. [pmid: 3621130].
Vasen HFA, Mecklin JP, Kahn PM, et al. The International Collaborative Group on Hereditary Non-Polyposis Colon Cancer.(ICG-HNPCC). Dis Colon Rectum. 1991;34:424-5. [pmid: 2022152].
Vatn MH, Stalsberg H. The prevalence of polyps of the large intestine in Oslo: An autopsy study. Cancer. 1982;49:819-25. [pmid: 7055790].
Vernon SW. Adherence to colorectal cancer screening. A brief overview. Ann NY Acad Sci. 1995;768:292-5. [pmid: 8526370].
Warneke J, Petrelli N, Herrera L, Nava H. Accuracy of colonoscopy for the detection of colorectal polyps. Dis Colon Rectum. 1992;35:981-5. [pmid: 1395987].
Waye JD, Lewis BS, Frankel A, Geller SA. Small colon polyps. Am J Gastroenterol. 1988;83:120-2. [pmid: 3341333].
Waye JD, Lewis BS, Yessayan S. Colonoscopy: A prospective report of complications. J Clin Gastroenterol. 1992;15:347-51. [pmid: 1294644].
Williams AR, Balasooriya, BAW, Day DW. Polyps and cancer of the large bowel: A necropsy study in Liverpool. Gut. 1982;123:835-42. [pmid: 7117903].
Williams CB, Macrae FA, Bartram C. A prospective study of diagnostic methods in adenoma follow-up. Endoscopy. 1982;14:74-8. [pmid: 7075563].
Winawer SJ, Flehinger BJ, Schottenfeld D, and Miller DG. Screening for colorectal cancer with fecal occult blood testing and sigmoidoscopy. J Natl Cancer Inst. 1993;85:1311-8. [pmid: 8340943].
Winawer SJ, Zauber AG, Gerdes H, et al. Risk of colorectal cancer in the families of patients with adenomatous polyps. N Engl J Med. 1996;334:82-7. [pmid: 8531963].
Winawer SJ, Zauber AG, Ho MN, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329:1977-81. [pmid: 8247072].
Winawer SJ, Zauber AG, O'Brien MJ, et al. The National Polyp Study. 1. Design, methods, and characteristics of patients with newly diagnosed polyps. The National Polyp Study Workgroup. Cancer. 1992;70(5 Suppl):1236-45. [pmid: 1511370].
Wingo PA, Tong T, Bolden S. Cancer statistics 1995. Cancer. 1995;45:8-30. [pmid: 8625085].
Young GP, St. John JB. Selecting an occult blood test for use as a screening tool for large bowel cancer. Front Gastrointest Res. 1991;18:135-56.
Zapka JG, Palmer RH, Hargraves JL. Relationship of patient satisfaction with experienced systems performance and health status. J Ambul Care Man. 1995;18:73-83.
Zarchy TM, Ershoff D. Do characteristics of adenomas on flexible sigmoidoscopy predict advanced lesions on baseline colonoscopy?. Gastroenterology. 1994;106:1501-4. [pmid: 8194695].