# Improving Screening Test Compliance

Evidence suggests that there is a low level of awareness about the risks of colorectal cancer and its symptoms among adults in the United States (Bostick, Sprafka, Virning, and Potter, 1993; Brown, Potosky, Thompson, and Kessler, 1990). Methods to improve screening compliance have been identified. Patients who understand the nature of the disease are more likely to feel that they may be at risk, perceive fewer barriers to testing, and be more likely to participate in screening (Brown, Potosky, Thompson, and Kessler, 1990, Blalock, DeVellis, and Sandler, 1987). In addition, good communication between health care providers and patients and effective use of educational materials can greatly enhance patient participation and satisfaction (Myers, Trock, Lerman, et al., 1990; Kelly and Shank, 1992; McCarthy and Moskowitz, 1993; Zapka, Palmer, and Hargrove, 1995).