# Screening People at Increased Risk

## Family History of Colorectal Cancer

There is evidence that cancers arise at an earlier age in people who have one or more first degree relative with colorectal cancer than in individuals considered to be at average risk for colorectal cancer. In effect, the risk of a 40-year-old man or woman with a family history of colorectal cancer is comparable to that of an average-risk individual of 50 (Fuchs, Giovannucci, Colditz, et al., 1994). The incidence in this group is increased about two-fold, and this increase appears to be greater in young adults than in older individuals (Fuchs, Giovannucci, Colditz, et al., 1994). Risk is higher if the relative developed colorectal cancer at a young age (St. John, Young, McHutchison, et al., 1992; Fuchs, Giovannucci, Colditz, et al., 1994). There is no evidence that cancer develops more rapidly in people with a family history of colorectal cancer. Similarly, the distribution of cancer in the colon and rectum is not substantially different in people with a family history of colorectal cancer compared with people at average risk.

It also has been shown that siblings and parents of patients with adenomatous polyps are at increased risk for colorectal cancer, particularly when the adenoma is diagnosed before the age of 60 or, in the case of siblings, when a parent has had colorectal cancer (Winawer, Zauber, and Gerdes, 1996).

## Genetic Syndromes

Genetic abnormalities for two inherited colorectal cancer syndromes - familial adenomatous polyposis (FAP) and hereditary nonpolyposis colorectal cancer (HNPCC) - have been identified. In both cases, specific genetic mutations have been found in the kindreds examined. However, it is not known what proportion of HNPCC carriers exhibit the genetic abnormalities that have been identified so far.

In people with confirmed FAP, approaches to prevention are based on the biologic behavior of the syndrome, which is well characterized. Screening is not an issue once persons with the syndrome have been identified. There are too many polyps to be evaluated individually, and the risk of cancer is high. Thus, colectomy is the only feasible preventive strategy for colorectal cancer in these patients.

Screening is relevant for people at risk for HNPCC because of a family history of the syndrome when they know from genetic testing that they carry the gene. There is evidence that cancers develop at an earlier age and at a much higher rate with a more proximal distribution than in people at average risk. However, evidence about the effectiveness of screening is sparse.