# Rationale for Screening

In the United States, the incidence of colorectal cancer is increasing, while the mortality rate is decreasing. The incidence of colorectal cancer increases with age and is higher in men than in women (60.4 versus 40.9 per 100,000 per year) (National Cancer Institute, 1990). Racial difference in colorectal cancer survival have been observed (Howard, Hankey, Greenberg, et al., 1992; Mayberry, Coates, Hill, et al., 1995). The 1983 to 1989 5-year relative survival for colon cancer was 61 percent among white men, 59 percent among white women, 48 percent among black men, and 49 percent among black women (Miller, Ries, Hankey, et al., 1992). Analyzing the National Cancer Institute's Black/White Cancer Survival Study, Mayberry and colleagues (1995) found that black men and women with colorectal cancer had a 50 percent greater probability of dying of colon cancer than did white men and women. Colorectal cancer mortality is low in American Indians and high in Alaska Natives (Baquet and Hunter, 1995). Such factors as differences in stage of disease at diagnosis, aggressiveness of therapy, and sociodemographic and cultural characteristics may contribute to the observed disparity in survival. However, none of these factors completely explains the disparity.

Blacks may have a more proximal distribution of adenomas and carcinomas than the general population; if true, full colonic examination would be essential for colorectal cancer screening in this population (Cordis and Johnson, 1991).

Colorectal cancers and adenomatous polyps are found throughout the colon and rectum, with about half occurring proximal to the splenic flexure (Rogge, Elmore, Mahoney, et al., 1994; Lieberman and Smith, 1991). Colorectal cancer is classified in stages according to the extent to which it has extended from its origin in the mucosa through the wall to the bowel, regional lymph nodes, and distant sites, especially the liver. Colorectal cancer survival is closely related to the clinical and pathologic stage of the disease at diagnosis. Up to 90 percent of patients with cancer limited to the bowel wall will be alive 5 years after diagnosis (Mandel, Bond, Church, et al., 1993), compared with 35 to 60 percent of those with involvement of the lymph nodes and less than 10 percent of patients with metastatic disease (Wingo, Tong, and Bolden, 1995).

Mucosal masses in the colon and rectum - described clinically as polyps - represent several kinds of histology with differing levels of clinical importance. They include: adenomatous polyps, which are premalignant and account for about half to two-thirds of all colorectal polyps; hyperplastic polyps, which make up 10 to 30 percent of all polyps, are generally small (< 0.5 cm in diameter), of no clinical importance, and tend to be located predominantly in the distal bowel; mucosal tags, which are also small and of no clinical importance, account for 10 to 30 percent of colorectal polyps; and a variety of other histologic types such as lipomas and hemartomas that are uncommon (Vatn and Stalsberg, 1982; O'Brien, Winawer, Zauber, Ho, et al., 1990).

Adenomatous polyps are found in about 25 percent of the population by age 50, and the prevalence increases with age. An estimate based on autopsy series is that the prevalence of adenomatous polyps is higher in men than women at any given age, reaching approximately 60 percent in men and 40 percent in women by age 80 (Blatt, 1961; Eide and Stalsberg, 1978; Rickert, Auerbach, Garfinkel, et al., 1979; Vatn and Stalsberg, 1982; Williams, Balasooriya, and Day, 1982). Among older individuals, a larger proportion of adenomas are found in the proximal bowel (Bernstein, Feczko, Halpert, et al., 1985; Vatn and Stalsberg, 1982; Granqvist, 1981).

The probability that an adenomatous polyp will progress to cancer and the probability that the patient will develop other adenomatous polyps or cancer elsewhere in the colon and rectum can be estimated from characteristics of the index polyp at the time it is first examined. The size of an adenomatous polyp is directly related to the probability that it will have high-grade dysplasia - considered to be the earliest indication of preinvasive cancer - and that other adenomatous polyps and cancer will develop elsewhere in the colon or rectum. In one study, 1.1 percent of adenomatous polyps < 5 mm in diameter, 4.6 percent of those 5-9 mm in diameter, and 20.6 percent of those 1 cm or larger had high-grade dysplasia (O'Brien, Winawer, Zauber, et al., 1990).

Information on the relationship between the characteristics of adenomas and the risk of cancer is provided by a British study of 1,618 patients, all of whom had adenomas removed from the rectum or sigmoid colon and were followed without additional testing for about 14 years per patient. Those whose original polyps were tubulovillous, villous, or large (> 1 cm in diameter) were more than three times more likely to develop colon cancer than people in the general population (Atkins, Morson, and Cuzick, 1992). Patients who had multiple rectosigmoid polyps with advanced pathology were more than six times more likely to develop colon cancer. Patients with single or multiple small (< 1 cm in diameter) tubular adenomas had a risk of subsequent cancer similar to that of the general population. These same polyp characteristics - size > 1 cm in diameter, tubulovillous or villous histology, and multiple occurrence - predict increased risk of developing further adenomatous polyps as well as cancer (Kronborg and Fenger, 1987).

Adenomatous polyps are considered to be the precursors of most colorectal cancers (Winawer, Zauber, Ho, et al., 1993). Few adenomatous polyps progress to cancer; the rate of progression is estimated to be about 2.5 polyps/1000/year (Eide, 1985). The transformation from small adenoma to cancer appears to occur slowly over many years. However, the average time and distribution of progression rates have not been determined. Direct observation of a small number of benign polyps and their progression to cancer suggests a time interval of 10 to 15 years (Morson, 1984). A case-control study by Selby and colleagues suggests that the protective effect of screening sigmoidoscopy lasts for up to 10 years (Selby, Friedman, Quesenberry, and Weiss, 1992), providing indirect evidence of an interval of at least 10 years from polyp development to progression to cancer.