# Summary and Implications

Wheeled mobility service delivery is not a new concept or technology, but elements related to the process (including funding, provider qualifications, and advances in technology) have undergone dramatic changes over the past few decades. These changes make it more difficult for providers, payers, and consumers to gain the appropriate knowledge and awareness necessary to ensure that all individuals with complex rehabilitation needs get the seating and mobility services and equipment most appropriate to their needs. The major finding of this work is the limited number of studies designed to evaluate the effectiveness of the recommended practices.

Guiding Question 4 includes the identification of issues and implications arising from the evidence reviewed in this report. The implications of the lack of sufficient evidence are far and wide. While there is general agreement among seating and mobility experts about how wheeled mobility service delivery should work in practice, without evidence of effectiveness, health care systems may not feel obligated to offer specialty clinics and ongoing services, and third party payers have no rationale for funding the recommended steps. Without adequate funding, providers and suppliers may need to limit the equipment and services they provide, and manufacturers may be reluctant to develop high quality products that may not reach consumers. A first step towards addressing these issues is the funding of high-quality research related to the wheeled mobility service delivery process. Once an evidence base is established, evidence reviews can be performed and evidence-based guidelines can be developed and validated.

To address Guiding Question 4, “Issues,” we focused on our review of the grey literature and our discussions with key informants. We also received suggestions from the public and peer review. We recognize the great potential for bias in the grey literature and in expert opinion. Given that limitation, we identified issues under the general categories of payer issues, provider issues, consumer issues, supplier issues, service delivery process issues, and research issues that may impact the ability of patients to obtain wheeled mobility equipment and services that match their needs.

## Payer and Reimbursement Issues

a. Payers have expressed concern about the increasing number of requests for power mobility devices. The lack of authoritative, easy to understand guidance supported by evidence to assist them in determining the most effective equipment for an individual may have resulted in the creation of more restrictive reimbursement policies.
b. Payers are unsure about the role of health insurers in the acquisition of equipment that addresses non-health-related needs (i.e., school and/or work needs).
c. Medicare covers seating and mobility services and equipment necessary for performance of mobility-related activities of daily living in the home. It is not realistic to assume that individuals will remain confined to their homes when one of the advantages of wheeled mobility is the greater capacity and endurance for community activities.
d. The type of chair for which an individual qualifies is determined by diagnosis as opposed to functional status. For many complex diseases and injuries that result in mobility limitation, the diagnosis may be the same but the functional abilities vary widely.
e. Under Medicare, individuals who rent wheeled mobility equipment for 13 months effectively own the device. This often catches individuals by surprise and, more importantly, makes them ineligible to be fitted for a more appropriate device until they reach the requisite replacement time.
f. Payers typically specify an amount of time (often 5 years) before a replacement chair will be approved regardless of the degree to which the equipment is used or whether the user’s health status has changed. This limitation may also apply if the initial equipment was inappropriate.
g. While payers struggle with questions regarding which individuals need which chairs, a more practical approach may be for them to trust the professionals trained to evaluate the patient and to select the ideal wheeled mobility equipment necessary for that patient. Current practice involves review by staff who have not evaluated the patient and who may not have sufficient knowledge of the patient’s need to evaluate the appropriateness of the recommended equipment. A peer review process might be an option. However, to trust the providers would require evidence relating provider types and process components to patient outcomes, an evidence base that does not yet exist. Once such evidence is available and synthesized, payers may be more willing to review issues such as whether the appropriate process was in place or the appropriate team of professionals was involved when determining the appropriateness of the equipment for the patient.

## Consumer Issues

a. Many individuals are ill-equipped to appropriately advocate for seating and mobility equipment and services they need because they lack necessary knowledge and awareness about the wheeled mobility delivery process and/or resources available to them to assist in advocating for their needs.
b. Access to providers who specialize in seating and mobility and to experienced, dependable suppliers may be a major obstacle in achieving an appropriate match between individuals and seating and mobility equipment and services, especially in rural areas.
c. Third-party payer networks may limit patient options by specifying the providers and vendors who will be reimbursed, by insufficient reimbursement, by annual caps on DME expenses, and by restricting use of private funds to upgrade equipment.

## Provider Issues

a. In recommending wheeled mobility equipment and services, providers must consider not only what they believe is right for the individual but also what will get reimbursed.
b. The medical model, with the physician responsible for the prescription and the letter of medical necessity, may not be the most appropriate model for all patients or all situations. Providers may lack the formal education and expertise needed.
c. Standard academic PT and OT professional education programs may not provide adequate education and training related to evaluation and technological assessment of wheeled mobility and seating devices.

## Supplier and Reimbursement Issues

a. Current Procedural Terminology (CPT) codes may not adequately reimburse providers for their services in assessing patients (especially individuals with complex medical or functional needs) and their environment (i.e., performing home, school, and/or workplace assessments), selecting the equipment (i.e., equipment trials), and delivering the equipment (i.e., fitting, training). Other limitations of the CPT coding system may result in inconveniences for patients and delays in delivery of equipment.
b. The Healthcare Common Procedure Coding System defines the reimbursement for categories of equipment but may not adequately distinguish between levels of complexity or quality within those categories. With decreasing reimbursements, there is concern that lower quality products are being offered and innovative designs are not reaching consumers. Additionally, the supplier is reimbursed for the equipment. Time spent training the user and/or adjusting the equipment is not directly reimbursed.
c. Recent Federal payment policy issues include reducing payments for DME by 9 percent and a proposed move towards requiring competitive bidding for DME.

## Service Delivery Issues

a. Underprescription of technology due to provider or supplier inexperience or concerns about reimbursement could result in a lower quality of life than could be realized with the provision of equipment with greater functional capabilities and services that enable users to benefit from the equipment. Overprescription or inappropriate prescription could result in wasted resources and/or harms to the user.
b. Few studies address outcomes when individuals obtain equipment from a vendor storefront or Web site or as a result of direct-to-consumer advertising.
c. The service delivery process differs for patients with short-term or minimal-use needs (such as after an injury) versus patients with complex medical rehabilitation needs (such as individuals with multiple sclerosis, cerebral palsy, spinal cord injury, or other disabling and potentially progressive mobility impairments). Stakeholders advocate for restructuring benefits for complex patients to address the delivery process differences.
d. Assessments of and recommendations for wheeled mobility equipment for individuals who may experience major changes over a short period (e.g., children, patients with progressive disease conditions) must take into consideration restrictions on the frequency of equipment replacement.
e. The presence of a supplier at a seating and mobility assessment is considered essential due to rapid changes in the technology and the need for experience with a broad array of products. However, there are potential economic incentives for the supplier and therefore selection of a reputable supplier is important. Certification of suppliers is a recent development.
f. Home (and school or workplace, if appropriate) assessments and equipment trials are important so that the needs and goals of the individual are assessed in the environments in which they function.
g. Outcomes assessment should focus on how the equipment provided meets the individual’s needs and goals.

## Research Issues

a. There is a need for research to enable the development of an evidence base for wheeled mobility service delivery. Using the patient, interventions, comparisons, and outcomes (PICO) approach, future research could address the effectiveness of the service delivery process for patients with different physical and cognitive limitations, funding sources, needs/goals (i.e., home, vocational), and support systems. Interventions could include different models of specialty seating and mobility clinics, telerehabilitation for patients without access to specialty clinics with comparisons to usual care, effectiveness of wheeled mobility device between and among types of professionals performing evaluations, and comparisons between provider teams with different members and provider qualifications. Outcomes to be studied could include functional abilities, comfort, and use, with the prescribed equipment, patient adverse events, and equipment breakdowns. Consistent use of standard validated outcome measures would enhance the quality of this body of research.
b. Research in this area is challenging due to issues related to study design, population, environments, and equipment variations.64 While conducting randomized controlled trials is extremely difficult in the rehabilitation field, progress on study design quality in this field could focus on conducting high quality, well-controlled prospective studies.
c. Funding agencies need to be willing to allocate resources for research in this area. The current focus is on new technologies.