# References

1 Brault M. Americans with disabilities: 2005. Current Population Reports. Washington, DC. U.S. Census Bureau. 2008:70-117.
2 Steinmetz E. Americans with Disabilities: 2002. Current Population Reports. Washington, DC. U.S. Census Bureau. 2006:70-117.
3 Kaye H, Kang T, LaPlante M. Wheelchair use in the United States. Disability Statistics Abstracts. 2002;23:1-4.
4 Cooper R, Cooper R. Trends and issues in wheeled mobility technologies. Paper presented at: International workshop on space requirements for wheeled mobility. 2003. Buffalo, NY. Available at: http://www.ap.buffalo.edu/ideaproto/Space%20Workshop/Papers/WEB%20-%20Trends_Iss_WC%20(Cooper).doc.
5 Cooper R. Wheeled mobility and manipulation technologies. The Bridge. 2009;39(1):13-20.
6 Russell JN, Hendershot GE, LeClere F, et al. Trends and differential use of assistive technology devices: United States, 1994. Advance Data. Nov. 13. 1997;(292):1-9. [pmid: 10182811].
7 Flagg J. Wheeled mobility demographics. Bauer S, ME B, editors. Industry profile on wheeled mobility. Buffalo, NY. Rehabilitation Engineering Center on Technology Transfer. 2009:7-29.
8 Salminen A-L, Brandt A, Samuelsson K, et al. Mobility devices to promote activity and participation: a systematic review. Journal of Rehabilitation Medicine. Sep. 2009;41(9):697-706. [pmid: 19774301].
9 Gavin-Dreschnack D, Nelson A, Fitzgerald S, et al. Wheelchair-related falls: current evidence and directions for improved quality care. Journal of Nursing Care Quality. Apr–Jun. 2005;20(2):119-127. [pmid: 15839290].
10 Kirby RL, Ackroyd-Stolarz SA. Wheelchair safety—adverse reports to the United States Food and Drug Administration. American Journal of Physical Medicine & Rehabilitation. Jul–Aug. 1995;74(4):308-312. [pmid: 7632389].
11 Xiang H, Chany A, Smith G. Wheelchair related injuries treated in US emergency departments. British Medical Journal. 2006;12(1):8-11.
12 Phillips B, Zhao H. Predictors of assistive technology abandonment. Assistive Technology. 1993;5(1):36-45. [pmid: 10171664].
13 Kittel A, Di Marco A, Stewart H. Factors influencing the decision to abandon manual wheelchairs for three individuals with a spinal cord injury. Disability & Rehabilitation. Jan. 10–Feb 15. 2002;24(1–3):106-114. [pmid: 11827144].
14 Armstrong W, Borg J, Krizack M, et al. Guidelines on the provision of manual wheelchairs in less-resourced settings. Borg J, Khasnabis C, editors. Geneva. World Health Organization. 2008.
15 National Coalition for Assistive and Rehab Technology (NCART). Proposal to create a separate benefit category for complex rehab technology. 2010. Available at: http://www.ncart.us/_webapp_3818728/Updated_Proposal_to_Create_Separate_Benefit_Category_for_Complex_Rehab_Technology.
16 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. International Journal of Epidemiology. Feb. 2002;31(1):115-123. [pmid: 11914306].
17 American Medical Association (AMA). Guidelines for the use of assistive technology: evaluation, referral, prescription. Chicago, IL. American Medical Association. 1996.
18 Paralyzed Veterans of America (PVA). Wheelchairs—Your Options & Rights. A Guide to Department of Veterans Affairs Eligibility. 2nd Ed. Paralyzed Veterans of America. 1997.
19 Department of Veterans Affairs. Clinical Practice Recommendations for Motorized Wheeled Mobility Devices. 2004.
20 Cooper R. Wheelchair selection and configuration. New York. Demos Medical Publishing, Inc. 1998.
21 Schmeler M, Buning M. The Lecture Series on Application and Use of Wheelchair Technology: Wheelchair Service Delivery. Available at: http://www.wheelchairnet.org/WCN_WCU/SlideLectures/Lectures/lectures.htm. Accessed August 10, 2010.
22 Minkel J. Service delivery in assistive technology. Olson D, DeRuyter F, editors. Clinician’s Guide to Assistive Technology. St. Louis. MO. 2002:55-65.
23 Clinician Task Force of the Coalition to Modernize Medicare Coverage of Mobility Products. Wheeled Mobility Device Coverage Policy Recommendations. 2004. Available at: http://www.cliniciantaskforce.us/report.php.
24 Cook A, Polgar J. Cook & Hussey’s Assistive Technologies: Principles and Practice. Mosby Elsevier. 2008.
25 Taylor SJ, Furumasu J. The clinician’s perspective. Bauer S, Buning ME, editors. The industry profile on wheeled mobility. Buffalo, NY. Rehabilitation Engineering Center on Technology Transfer. 2009:258-87.
26 Batavia M. The Wheelchair Evaluation: A Clinician’s Guide. Jones & Bartlett Publishers. 2010.
27 Amsterdam P. Considerations in pediatric wheelchair assessments. Case Manager. Sep–Oct. 1999;10(5):20-22. [pmid: 11094949].
28 Cox DI. Not your parent’s wheelchair. Rehab Management. Aug–Sep. 2004;17(7):26-27. [pmid: 15373352].
29 Daus C. The right fit. Rehab Management. Aug–Sep. 2003;16(7):32-35. [pmid: 12961997].
30 Hundertmark LH. Evaluating the adult with cerebral palsy for specialized adaptive seating. Physical Therapy. Feb. 1985;65(2):209-212. [pmid: 3969402].
31 Leonard RB. Seating and mobility issues for polio survivors. Rehab Management. Jun–Jul. 1997;10(4):44-46. [pmid: 10168567].
32 Canning B, Sanchez G. Considering powered mobility for individuals with stroke. Topics in Stroke Rehabilitation. 2004;11(2):84-88. [pmid: 15118971].
33 Eberhard K, Finlayson M. Wheeled mobility for people with MS: environmental and lifestyle considerations. International Journal of MS Care. 2005;7(3):101-106.
34 Dworak P, Folland R, Kirkner A. Age over matter. Seating geriatric patients takes a thorough understanding of their health and lifestyle. Rehab Management. 2004;10(26):28-29.
35 Sabol TP, Haley ES. Wheelchair evaluation for the older adult. Clinics in Geriatric Medicine. May. 2006;22(2):355-375. [pmid: 16627083].
36 Di Marco A, Russell M, Masters M. Standards for wheelchair prescription. Australian Occupational Therapy Journal. 2003;50(1):30-39.
37 Ripat J, Booth A. Characteristics of assistive technology service delivery models: Stakeholder perspectives and preferences. Disability & Rehabilitation. 2005;27(24):1461-1470. [pmid: 16421071].
38 Eggers SL, Myaskovsky L, Burkitt KH, et al. A preliminary model of wheelchair service delivery. Archives of Physical Medicine & Rehabilitation. Jun. 2009;90(6):1030-1038. [pmid: 19480881].
39 Centers for Medicare & Medicaid (CMS). Medicare National Coverage Determinations Manual (Chapter 1, Part 4). Centers for Medicare and Medicaid Services. Centers for Medicare & Medicaid. Available at: https://www.cms.gov/manuals/downloads/ncd103c1_Part4.pdf.
40 Centers for Medicare & Medicaid Sevices (CMS). Medicare Coverage Database. Decision Memo for Mobility Assistive Equipment (CAG-00274N). Centers for Medicare & Medicaid Services. Available at: http://www.cms.gov/mcd/viewdecisionmemo.asp?from2=viewdecisionmemo.asp&id=143&. Accessed June 22, 2010.
41 ECRI Institute. Interagency Wheelchair Work Group Policy Review for Power Mobility Devices. ECRI Institute. Available at: https://www.ecri.org/Documents/EPC/Interagency_Wheelchair_Work_Group_Policy_Review_for_Power_Mobility_Devices.pdf. Accessed September 11, 2010.
42 Centers for Medicare & Medicaid (CMS). Medicare Program; Conditions for Payment of Power Mobility Devices, Including Power Wheelchairs and Power-Operated Vehicles. Centers for Medicare & Medicaid. Available at: http://edocket.access.gpo.gov/2006/pdf/06-3271.pdf. Accessed September 11, 2010.
43 Centers for Medicare & Medicaid (CMS). Durable Medical Equipment, Prosthetics, Orthotics, and Supplies (DMEPOS) Quality Standards. Centers for Medicare & Medicaid Services. Available at: http://www.cms.gov/MedicareProviderSupEnroll/Downloads/DMEPOSAccreditationStandardsCMB.pdf. Accessed August 10, 2010.
44 Isaacson M. Only the best: today’s best seating and mobility practices may be tomorrow’s standards. Rehab Management. Oct. 2004;17(8):34-37. [pmid: 15535357].
45 Wantanabe L. Earning the ATP—4 things you need to know about RESNA’s new SMS. Available at: http://mobilitymgmt.com/Articles/2010/04/01/RESNA-New-SMS.aspx?p=1. Accessed May 21, 2010.
46 National Registry of Rehabilitation Suppliers (NRRTS). National Registry of Rehabilitation Suppliers (NRRTS).
47 Nitz JC. Evidence from a cohort of able bodied adults to support the need for driver training for motorized scooters before community participation. Patient Education & Counseling. Feb. 2008;70(2):276-280. [pmid: 18065187].
48 CSM. Clinical Practice Guideline: Preservation of Upper Limb Function Following Spinal Cord Injury: Paralyzed Veterans of America Consortium for Spinal Cord Medicine. 2005.
49 Scherer M. Matching consumers with appropriate assistive technologies. Olson D, DeRuyter F, editors. Clinician’s Guide to Assistive Technology. St. Louis, MO. Mosby. 2002:3-13.
50 Kilkens OJE, Post MWM, Dallmeijer AJ, et al. Relationship between manual wheelchair skill performance and participation of persons with spinal cord injuries 1 year after discharge from inpatient rehabilitation. 3rd International Congress on the restoration of (wheeled) mobility in SCI rehabilitation: state of the art III. Amsterdam. April 2004. Journal of Rehabilitation Research & Development. 2005;42(3):65-73.
51 Hansen R, Tresse S, Gunnarsson RK. Fewer accidents and better maintenance with active wheelchair check-ups: a randomized controlled clinical trial. Clinical Rehabilitation. 2004;18(6):631-639. [pmid: 15473115].
52 Batavia AI, Hammer GS. Toward the development of consumer-based criteria for the evaluation of assistive devices. Journal of Rehabilitation Research & Development. 1990;27(4):425-436. [pmid: 2089152].
53 Ward AL, Sanjak M, Duffy K, et al. Power wheelchair prescription, utilization, satisfaction, and cost for patients with amyotrophic lateral sclerosis: preliminary data for evidence-based guidelines. Archives of Physical Medicine & Rehabilitation. Feb. 2010;91(2):268-272. [pmid: 20159132].
54 McDonald RL, Surtees R, Wirz S. A comparative exploration of the thoughts of parents and therapists regarding seating equipment for children with multiple and complex needs. Disability Rehabilitation - Assistive Technology. Nov. 2007;2(6):319-325. [pmid: 19263562].
55 Telfer S, Solomonidis S, Spence W. An investigation of teaching staff members’ and parents’ views on the current state of adaptive seating technology and provision. Disability & Rehabilitation: Assistive Technology. 2010;5(1):14-24. [pmid: 19941437].
56 Beaumont-White S, Ham R. Powered wheelchairs: are we enabling or disabling?. Prosthetics and Orthotics International. 1997;21(1):62-73. [pmid: 9141127].
57 Karmarkar A, Collins D, Kelleher A, et al. Satisfaction related to wheelchair use in older adults in both nursing homes and community dwelling. Disability & Rehabilitation: Assistive Technology. 2009;4(5):337-343. [pmid: 19565374].
58 Pimentel S. Goal setting and outcome measurement in a wheelchair service: a client-centred approach including commentary by Tanner B, Finney L. International Journal of Therapy & Rehabilitation. 2008;15(11):491-499.
59 Wressle E, Samuelsson K. User satisfaction with mobility assistive devices. Scandinavian Journal of Occupational Therapy. 2004;11(3):143-150.
60 White E, Lemmer B. Effectiveness in wheelchair service provision. The British Journal of Occupational Therapy. 1998;61(7):301-305.
61 Barlow I, Liu L, Sekulic A. Wheelchair seating assessment and intervention: A comparison between telerehabitation and face-to-face service. International Journal of Telerehabilitation. 2009;1(1):11.
62 Schein RM, Schmeler MR, Holm MB, et al. Telerehabilitation wheeled mobility and seating assessments compared with in person. Archives of Physical Medicine & Rehabilitation. Jun. 2010;91(6):874-878. [pmid: 20510977].
63 Hoenig H, Landerman LR, Shipp KM, et al. A clinical trial of a rehabilitation expert clinician versus usual care for providing manual wheelchairs. Journal of the American Geriatrics Society. Oct. 2005;53(10):1712-1720. [pmid: 16181170].
64 Hoenig H, Pieper C, Branch LG, et al. Effect of motorized scooters on physical performance and mobility: a randomized clinical trial. Archives of Physical Medicine & Rehabilitation. Mar. 2007;88(3):279-286. [pmid: 17321817].
65 Dicianno BE, Gaines A, Collins DM, et al. Mobility, assistive technology use, and social integration among adults with spina bifida. American Journal of Physical Medicine & Rehabilitation. Jul. 2009;88(7):533-541. [pmid: 19542778].
66 Samuelsson K, Larsson H, Thyberg M, et al. Wheelchair seating intervention. Results from a client-centred approach. Disability and rehabilitation. 2001;23(15):677. [pmid: 11720118].
67 Evans S, Neophytou C, de Souza L, et al. Young people’s experiences using electric powered indoor—outdoor wheelchairs (EPIOCs): potential for enhancing users’ development?. Disability & Rehabilitation. Aug. 30. 2007;29(16):1281-1294. [pmid: 17654003].
68 Samuelsson K, Wressle E. User satisfaction with mobility assistive devices: an important element in the rehabilitation process. Disability & Rehabilitation. 2008;30(7):551-558. [pmid: 17852301].
69 Evans S, Frank AO, Neophytou C, et al. Older adults’ use of, and satisfaction with, electric powered indoor/outdoor wheelchairs. Age & Ageing. Jul. 2007;36(4):431-435. [pmid: 17384418].
70 Garber S, Bunzel R, Monga T. Wheelchair utilization and satisfaction following cerebral vascular accident. Journal of Rehabilitation Research and Development. 2002;39(4):521-534. [pmid: 17638149].
71 Bergstrom AL, Samuelsson K. Evaluation of manual wheelchairs by individuals with spinal cord injuries. Disability & Rehabilitation Assistive Technology. Jun. 2006;1(3):175-182. [pmid: 19260185].
72 Suzuki KM, Lockette G. Client satisfaction survey of a wheelchair seating clinic. Physical & Occupational Therapy in Geriatrics. 2000;17(2):55-65.
73 Post MW, van Asbeck FW, van Dijk AJ, et al. Services for spinal cord injured: availability and satisfaction. Spinal Cord. Feb. 1997;35(2):109-115. [pmid: 9044519].
74 Richardson M, Frank AO. Electric powered wheelchairs for those with muscular dystrophy: problems of posture, pain and deformity. Disability & Rehabilitation Assistive Technology. May. 2009;4(3):181-188. [pmid: 19199130].
75 National Center for Physical Activity and Disability. Lifetime Sports: Wheelchairs. University of Illinois at Chicago, Department of Disability and Human Development. Available at: http://www.ncpad.org/lifetime/fact_sheet.php?sheet=110&section=828. Accessed January 14, 2011.
76 Boninger M, Cooper R, Schmeler M, et al. Chapter 59—Wheelchairs. DeLisa JAG, Bruce M, editors. Ovid Technologies, Inc. Physical Medicine & Rehabilitation: Principles and Practice. 4. Philadelphia, PA. Lippincott Williams & Wilkins. 2005.
77 World Health Organization (WHO). Guidelines on the Provision of Manual Wheelchairs in Less Resources Settings. Geneva. World Health Organization. 2008.