# Next Steps

The issues identified and compiled in this Technical Brief deserve further attention. Research is needed to investigate and identify factors that contribute to effective wheeled mobility service delivery. The importance of funding this type of research needs to be recognized and reliable, and valid outcome measures need to be developed.

The resulting evidence will guide providers, payers, and consumers. Intriguing concepts (such as seating and mobility specialist certification, added emphasis on seating and mobility assessment in the normative model for PT and OT education, supplier accreditation, specialized seating clinics, and multifactorial seating interventions) need evidence to demonstrate whether they will lead to more effective wheeled mobility provision, thereby justifying the additional resources. Components of service delivery (such as consumer-focused evaluations, consumer training, and followup) need more rigorous evaluation to demonstrate their relationship to effectiveness so that a case can be made to initialize reimbursement-related incentives for their provision. Further exploration and diffusion of telerehabilitation to alleviate access issues to individuals in geographically isolated areas is another high-priority research topic. Research findings should be incorporated into best practice guidelines for providers and educational materials for consumers and caregivers.

This Technical Brief focuses on the process of wheeled mobility service delivery and aspects of that process that may affect the quality of the match between an individual and their wheeled mobility device. There are many existing studies that address a device or a specific feature of the device and the relationship to outcomes. Those studies were beyond the scope of this study. However, a comprehensive review of this body of research would be a valuable contribution to clinical decisionmaking in this field.