# Methods

The objectives of this report are to describe the wheeled mobility service delivery process from various perspectives, to survey the evidence pertaining to the process of wheeled mobility service delivery, and to identify issues and areas for future research.

## Data Collection

We identified and utilized a variety of information sources, including key informants, published, peer-reviewed literature, and grey literature. These resources informed the descriptions of the Technology and the Context questions and provided guidance in the development of the Issues question. For the Evidence question, we conducted a systematic search of the peer-reviewed published literature.

Discussions with key informants. We identified wheeled mobility service delivery providers, third-party payers, consumers, suppliers, and researchers to serve as key informants to provide expertise from various perspectives. Key informants initially participated in discussions aimed at developing the guiding questions for the Technical Brief and provided leads to resources in the peer-reviewed and grey literature. These individuals, their perspectives, and affiliations are listed in Appendix B (Table B1). Every attempt was made to include a wide and comprehensive group of knowledgeable individuals who represented a broad range of relevant occupations and organizations and were able to provide input from several perspectives. Individual interviews were then conducted via telephone or in person, if logistically feasible, during June and July 2010. The interviews were designed and conducted to gather information pertaining to the guiding questions. Information requested from each key informant varied based upon their area or expertise and/or perspective with regard to wheeled mobility service delivery. Structured discussion questions were developed in advance of interviews to ensure that necessary information was solicited in a timely manner. A listing of these questions appears in Appendix B (Table B2).

Grey Literature Search. Grey literature on this topic was important to provide background and context to the topic. It also provided insight into current issues regarding wheeled mobility service delivery. A targeted approach to searching the grey literature was conducted and included bibliographic databases such as ProQuest Digital Dissertations and topic specific databases such as those maintained by the National Rehabilitation Information Center (NARIC) [REHABDATA, National Institute on Disability and Rehabilitation Research (NIDRR) Project Database, and the NARIC Knowledgebase]. Grey literature searching also included searches of related conference abstracts (i.e., International Seating Symposium, Rehabilitation Engineering and Assistive Technology Society of North America (RESNA) Annual Conference). Payment policies were obtained by searching relevant online databases, such as the Medicare Coverage database, and through targeted requests for information. Web sites of relevant not-for-profit organizations and government agencies were searched for information and publications. Relevant Web sites included those published by the RESNA, the Christopher and Dana Reeve Foundation, Paralyzed Veterans of America, the National Coalition of Assistive and Rehabilitation Technology, and others. Quality of Web site information was evaluated to ensure that the information provided was authoritative, up to date, had minimal ties to for-profit interests as appropriate, utilized references to scientific information, and provided names and credentials of Web site contributors. Grey literature was utilized primarily in addressing the descriptive guiding questions (Questions 1, 2, and 4).

Published Literature Search. We conducted literature searches in MEDLINE, the Cumulative Index to Nursing and Allied Health Literature (CINAHL), and the Education Resources Information Center (ERIC) from the earliest time permitted electronically until March 14, 2011. Searches were limited to studies relevant to humans and published in English. Restricting the research to English language materials was not expected to result in a language bias for this topic and stakeholders.16 Due to the limitations of the Medical Subject Headings (MeSH terms) and the relatively inconsistent use of terminology in this field, a search strategy with maximum recall potential was used. The purpose of the published literature search was to identify studies that addressed some component of the wheeled mobility service delivery process and its relationship with a wheeled mobility outcome such as use or satisfaction whit the device or service. We also conducted a manual search of references from reports of relevant studies or review articles. The search strategy used with Ovid MEDLINE and guiding searches of CINAHL and ERIC, including a concept analysis and proposed search terms, is described in Appendix C.

Results from the bibliographic database searches were screened for inclusion based on title and abstract, if available. Full text articles were retrieved when warranted by the title and/or abstract. All publication types were included if they related to the guiding questions. Only information related to wheeled mobility service delivery elements and outcomes was abstracted for studies that included more than one intervention. The exclusion criteria below were applied to studies resulting from the bibliographic database searches:

1. Does not address components of the wheeled mobility service delivery process and their relationship to wheeled mobility user outcomes (i.e., studies of individuals using wheelchairs and their quality of life without addressing aspects of the service delivery process).
2. Addresses aspect of wheeled mobility not relevant to guiding questions:
  a. Wheeled mobility used outside of routine activities around home and community (i.e., sports chairs, standing chairs, etc.)
  b. Very specific aspect of seating and mobility (i.e., types of seat cushions, joysticks, specific brands of chairs or seating materials, etc.)
  c. Outdated technology
  d. Research and development on equipment not currently widely available
3. Addresses creation, validation, or research on particular outcome measurement instruments.