# Guiding Questions

Consistent with the Technical Brief format and based on input from nominators of the topic, we developed guiding questions pertaining to the four Technical Brief areas (technology, context, evidence, and issues). We used these questions to guide our literature searches and our discussions with Key Informants.

Guiding Question 1. Technology. What criteria (i.e., medical conditions, physical characteristics, functional and/or vocational needs, environmental factors, etc.) do assessors and payers (including Medicare, Medicaid, Veterans Affairs (VA), and others) take into consideration when determining the appropriateness and medical necessity of a wheelchair type (i.e., manual, power scooter, power chair) and features (i.e., seating, tilt, etc.) for an individual patient?

a. What formal criteria exist?
b. How do the criteria differ across assessors?
c. How do the criteria differ across payers?
d. How do the criteria differ for patients of different ages (i.e., 21 years old and younger versus older than 21 years)?

Guiding Question 2. Context. Which of the following elements have been studied with regard to facilitating or hindering achievement of an appropriate patient/wheelchair match?

a. Provider type (i.e., occupational therapy, physical therapy, primary care provider, physiatrist).
b. Provider qualifications (i.e., certification, experience performing wheelchair assessments).
c. Setting (i.e., primary care clinic, specialty clinic, school, retail store).
d. Payer (i.e., Medicare, Medicaid, VA, Vocational Rehabilitation, private insurance).
e. Components of patient assessment (i.e., diagnosis versus functional abilities, cognitive abilities, physical abilities).
f. Assessment, prescription, and delivery steps (i.e., access, number of visits covered by insurance, trials and simulations with wheelchair, education and/or training provided to the patient, followup, etc.).

Guiding Question 3. Evidence. What studies have reported on wheeled mobility service delivery? Specifically, describe the following elements of the studies:

a. Indication/patient inclusion criteria.
b. Study design/size.
c. Elements of service delivery (i.e., patient physical characteristics, environmental factors, needs [functional, vocational], cognitive ability, provider, payer, fitting process [trials], counseling/training/education, followup).
d. Outcomes assessed (i.e., functional ability, utilization of chair, patient satisfaction, quality of life).
e. Adverse events/harms/safety issues (i.e., pressure sores, injuries, need for repairs, need for replacement).

Guiding Question 4. Issues. What are the important issues surrounding wheeled mobility service delivery? What are the topic areas, research designs, populations, interventions, comparators, outcome measures, and settings for future research into the most effective and efficient approach to matching patients with appropriate wheeled mobility devices?