# Executive Summary

Wheeled mobility service delivery is the process by which an individual obtains a wheeled mobility device. The process typically includes patient evaluation, equipment selection and delivery, and postdelivery training and followup. The purpose of this Technical Brief is to describe the wheeled mobility service delivery process, outline the criteria used by stakeholders in decisionmaking, survey the evidence on service delivery, and identify issues and areas for future research. The focus is on service delivery for long-term wheelchair users with complex rehabilitation needs. Information was gathered from discussions with key informants and searches of the grey and the published literature.

Recommended steps in the service delivery process were identified in textbooks, guidelines, and published literature. Overall, many elements common to all processes were identified. Recommendations to include equipment trials, formal followup, and outcome assessment were less uniform. Twenty-one studies pertaining to wheeled mobility service delivery were identified in the published literature. The majority were observational, exploratory studies designed to determine consumer use of and satisfaction with the wheeled mobility service delivery process. The major finding of this work is the limited number of studies designed to evaluate the effectiveness of the recommended practices. Additional research is needed to develop an evidence base on the topic of wheeled mobility service delivery. Researchers in this field should focus on provider types and process steps necessary to match patients with optimal wheeled mobility devices for their needs. Studies should incorporate the highest quality study designs feasible for this population. This evidence, once available, will be useful in the development of standards and guidelines necessary for evidence-based service delivery. Other issues with respect to wheeled mobility service delivery are identified and discussed.