# Background

Wheeled mobility or wheelchair use in the United States is at an all-time high and growing. A 2005 survey of noninstitutionalized Americans estimated that approximately 3.3 million people (1.4 percent of the population) 15 years of age and older used a wheelchair or similar device. Of those 3.3 million, approximately 1.8 million were 65 years and older (5.2 percent of that population). Among children under 15 years of age, an estimated 83,000 used a wheelchair or similar device (0.2 percent of that population).1 A similar survey conducted in 2002 estimated use at 1.2 percent of the population 15 years and older, 4.5 percent of the population 65 years and older, and 0.2 percent of the population under 15 years of age.2 An earlier survey (1994–1995 data) of noninstitutionalized individuals in the United States estimated that there were 1.6 million (0.6 percent) wheelchair users of all ages including 88,000 under age 18 years (0.12 percent) and 897,000 (2.87 percent) 65 years of age and older. Of the total group of wheelchair users, 1.5 million used manual wheelchairs and 155,000 used electric wheelchairs. The leading conditions associated with wheelchair use included stroke, osteoarthritis, multiple sclerosis, absence or loss of lower extremity, paraplegia, orthopedic impairment of lower extremity, heart disease, cerebral palsy, rheumatoid arthritis, and diabetes.3

At the same time that the population of mobility-impaired individuals is growing, advances have been made in mobility device and component technology.4,5 Although difficult to quantify, there appears to be increased use of power mobility devices, including power wheelchairs and scooters or power-operated vehicles.4,6,7 Advances in wheeled mobility offer enhanced functionality. Mobility devices have been shown to increase the activity, participation, and quality of life of individuals with mobility limitations.8 The degree to which these wheeled mobility devices and components (notably postural seating and positioning systems) contribute to quality of life depends on the appropriateness of the wheeled mobility device selected for the patient and their utilization of the device. However, inappropriate mobility devices may result in harms (including overuse or repetitive strain injuries, pressure sores, falls, and accidents), equipment abandonment, and underutilization.9–13

Wheeled mobility service delivery is the process by which mobility impaired individuals are matched to wheeled mobility devices and provided service. The process has been described by providers, patient organizations, and others. The World Health Organization (WHO) identified the following steps: (a) referral and appointment, (b) assessment, (c) prescription (selection), (d) funding and ordering, (e) product preparation, (f) fitting, (g) user training, and (h) followup, maintenance, and repairs.14 To maximize the benefit of scarce resources, matching patients with mobility limitations with the most appropriate wheeled mobility device, therefore avoiding under- and overprescribing, is paramount. However, many patients, providers, and payers may not be aware of or fully understand the aspects of wheeled mobility service delivery that likely contribute to attaining the most appropriate match between individual and equipment, features, and services.

Interest in identifying an evidence-based wheeled mobility service delivery process that could guide decisionmaking regarding coverage for individually configured mobility equipment and associated services, often referred to as Complex Rehab Technology (CRT),15 prompted the nomination of this topic. Evidence based guidelines for best practice might address areas such as critical components of the assessment and followup, selection of appropriate equipment based on patient needs, essential members of the service delivery team, provider qualifications, and frequency of reassessment.

To address this need, we prepared a Technical Brief to identify and describe the literature and expert opinion regarding the process of wheelchair service delivery for long-term wheelchair users with complex rehabilitation needs (i.e., individuals with a primary diagnosis resulting from a congenital disorder, progressive or degenerative neuromuscular disease, or from certain types of injury or trauma who will require a wheelchair for mobility beyond a period of rehabilitation).15 The Brief provides background information on the wheeled mobility service delivery process for stakeholders interested in wheelchair service delivery, including researchers, patients, providers, suppliers, and payers of wheeled mobility. It also identifies patient, provider, supplier, and payer issues that may impact the service delivery process. We recognize that consumers may obtain wheeled mobility devices from a variety of sources. We have focused on service delivery for individuals whose complex rehabilitation needs most likely will require contributions from physicians, therapists, suppliers, and technicians.

Technical Briefs are products of the Effective Health Care Program on topics which have been determined to be underdeveloped in terms of the availability of high-quality studies, typically topics that represent new technologies or concepts. Their purpose is much different than the purpose of more thorough and comprehensive effectiveness or comparative effectiveness review. The key difference is that while Technical Briefs do search for evidence on the topic and report that the evidence exists, because the evidence is predetermined to be insufficient to draw conclusions regarding the effectiveness of the relevant intervention, synthesis of the evidence is not conducted. Therefore, the contribution of a Technical Brief is to describe what evidence exists and identify topics where research in this field may enhance the quality of the evidence in the future and not to provide synthesized evidence regarding a particular technology or concept. A second purpose of the Technical Brief is to provide an overview of key issues related to a clinical intervention or health care service. Data presented in a Technical Brief cannot be used to develop standards or guidelines, to endorse one practice over another, or to inform policy or payment decisions, but are useful in providing direction on next steps necessary to move the topic in the direction of the development of an evidence base from which to accomplish these goals.

There exists unique terminology and prevalent diseases and conditions related to this topic. A listing of key terms and abbreviations can be found in Appendix A.