# Appendixes

Appendix A Terminology and Abbreviations

Appendix B Key Informants and Potential Questions

Appendix C Search Strategy

Appendix D Evidence Tables