# Evidence Tables

Table D1 Models and descriptions of wheeled mobility service delivery

Table D2 Studies of wheeled mobility service delivery