# Search Strategy

## Concept Analysis

Two concepts related to all key questions addressed in this Technical Brief; therefore, one search strategy was used in multiple bibliographic databases. The concepts included wheeled mobility and patient assessment. Table C1 explains the concept analysis and terminology that was used in searching Ovid MEDLINE. MeSH terms (or other terms relevant to the specific bibliographic database as determined by database thesaurus) and text words (with truncation used as necessary) relating to each concept were aggregated. Concepts were combined together to compile a set of literature inclusive of both concepts for screening. Limitations imposed on the Ovid MEDLINE search (and other databases if available) included human studies published in English. The search process was an iterative process with updates to restrict or expand the search as new terms were identified and the search process and resulting sets of literature were analyzed.

Table C1 Identification of search terms for relevant concepts

| Concept
| Wheeled Mobility | Service Delivery
Search terms [MeSH] and text words | Wheelchairs [MeSH] | assess$.tw.
Search terms [MeSH] and text words | wheelchair$.tw. | evalu$.tw.
Search terms [MeSH] and text words | scooter$.tw. | select$.tw.
Search terms [MeSH] and text words | “power mobility device$” | prescri$.tw.
Search terms [MeSH] and text words | “wheel chair$”.tw. | match$.tw.
Search terms [MeSH] and text words | “wheeled mobility”.tw. | “service delivery”.tw.
Search terms [MeSH] and text words | powerchair$.tw. | provi$.tw.
Search terms [MeSH] and text words | “power chair$”.tw. | acquir$.tw.
Search terms [MeSH] and text words | (“assistive technolog$” and “mobility”).mp. | procur$.tw.
Search terms [MeSH] and text words | [mp=abstract, heading words, title] | fit$.tw.
Search terms [MeSH] and text words | “seating clinic”.tw. | recommend$.tw.
Search terms [MeSH] and text words | | purchas$.tw.
Search terms [MeSH] and text words | | refer$.tw.
Search terms [MeSH] and text words | (seating and mobility).mp. [mp=abstract, heading words, title]

## MEDLINE Search Strategy

1. *Wheelchairs
2. wheelchair$.tw.
3. scooter$.tw.
4. “power mobility device$”.
5. “wheel chair$”.tw.
6. “wheeled mobility”.tw.
7. powerchair$.tw.
8. “power chair$”.tw.
9. (“assistive technolog$” and “mobility”).mp. [mp=abstract, heading words, title]
10. “seating clinic”.tw.
11. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
12. assess$.tw.
13. evalu$.tw.
14. select$.tw.
15. prescri$.tw.
16. match$.tw.
17. “service delivery”.tw.
18. provi$.tw.
19. acquir$.tw.
20. procur$.tw.
21. fit$.tw.
22. recommend$.tw.
23. purchas$.tw.
24. refer$.tw.
25. 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24
26. 11 and 25
27. (seating and mobility).mp. [mp=abstract, heading words, title]
28. 26 or 27
29. limit 28 to (english language and humans)
30. limit 29 to (addresses or biography or case reports or dictionary or directory or in vitro or legal cases or news or newspaper article or portraits)
31. 29 not 30