# Key Informants and Potential Questions

Table B1 Key informants

Name | Affiliation | Recommendation and Topic Area
Edward Amaya, M.B.A., RT (R), CPM | Ohio Department of Job and Family Services | Recommended by topic nominator, Mary Applegate Payer representative
Kory Badertscher, OT, ATP | Veterans Health Administration Minneapolis, MN | Recommended by EPC team member contact Local practitioner
Tim Caruso, PT, M.B.A., M.S., Cert. MDT, CEAS | Shriners Hospital for Children Chicago, IL | Recommended by EPC team Pediatric wheeled mobility expert
Donald E. Clayback | Executive Director N.C.A.R.T | Recommended by another key informant Wheelchair benefits expert; supplier and manufacturer representative
Laura Cohen, PT, Ph.D., ATP | Rehabilitation & Technology Consultants, LLC Atlanta, GA | Recommended by topic expert Rory Cooper, Ph.D. National content expert, researcher
Elizabeth Leef | Administration on Aging | Recommended by another key informant Consumer representative
Alison Little, M.D., M.P.H. | Center for Evidence-based Policy Oregon Health and Sciences University | Recommended by SRC Medicaid perspective
Colleen Michals, PT, ATP | Courage Center Golden Valley, MN | Recommended by EPC team member contact Local practitioner
Jeanne Olson | Courage Center Golden Valley, MN | Recommended by EPC team member contact Local content expert
Stephen Sprigle, Ph.D., PT | Professor of Applied Physiology, Bioengineering & Industrial Design Georgia Institute of Technology | Recommended by another key informant Researcher
David Williams | Chairman, Ohio Rehabilitation Services Commission | Recommended by another key informant Consumer representative
Becky Wittig, PT, ATP | Veterans Health Administration Minneapolis, MN | Recommended by EPC team member contact Local practitioner

Table B2 Structured discussion questions for key informant interviews

Key Informant Perspective | Potential Questions
Payers | 1. Do you have any guidelines/checklists that you use?; 2. Do you perceive any barriers in service delivery?; 3. Are there ways to make the process better?; 4. What impact does the provider and/or setting have on the process?; 5. What research would you like to see completed?
Providers/Assessors | 1. What guidelines/checklists do you use (or are you aware of)?; 2. Describe the delivery process (from initial contact to final delivery).; 3. What are the barriers to achieving a successful match of patient and wheelchair?; 4. How can the process be improved?; 5. How could future research help you in your practice?
Equipment Suppliers | 1. How do you perceive your role in the service delivery process?; 2. What prevents the ideal patient/wheelchair match?; 3. Is there technology that is not getting to the patients? If so, why?; 4. How does product research and development interface with the delivery process?
Researchers | 1. Are you aware of any research on the delivery process (or aspects of it)?; 2. What are the barriers to research on the delivery process?; 3. What are the key areas for future research?
Patients/Patient Advocates | 1. What has your experience been with different types of payers?; 2. What has your experience been with different types of providers?; 3. What has your experience been in different settings?; 4. What barriers do patients face in the typical wheelchair delivery process?; 5. What prevents patients from getting the “ideal” wheelchair for their needs?