# Terminology and Abbreviations

Terminology
Complex Rehabilitation Technology: “Individually configured manual wheelchair systems, power wheelchair systems, adaptive seating systems, alternative positioning systems, and other mobility devices.15”
Manual Wheelchair: Self-propelled chairs for disabled individuals with the upper body movement and strength sufficient to propel the chair by pushing the rims of the chair. These chairs come in a variety of sizes, materials, and designs and can offer a wide array of features.75,76
  - Lightweight manual wheelchairs—weigh less than 34 pounds without footrests or armrests. These chairs can be sized to the user, but often do not offer features that allow for substantial adjustability.76
  - Ultralight manual wheelchairs—weigh less than 30 pounds without foot or arm supports. These chairs are the highest-quality chairs designed specifically as an active mobility device. They are highly adjustable and offer features that improve ease of use and comfort.76
Mobility Assistive Equipment (MAE): Manual wheelchairs, power wheelchairs, scooters; also includes canes and walkers.
Power Wheelchair: Chairs that use a battery-powered motor that propels wheels; used by people with little to no movement in the upper body and limbs. These chairs come in a variety of configurations. Components of power wheelchairs include a power base which contains the wheels and electronics. The base provides for a variety of seating systems and seat functions to be attached.75,76

Acronyms and Abbreviations
ADL: activities of daily living
AT: assistive technology
ATP: assistive technology professional
CF: cystic fibrosis
CMS: Centers for Medicare & Medicaid Services
CP: cerebral palsy
CPT: current procedural terminology
DME: durable medical equipment
EPIOC: electronically powered indoor/outdoor wheelchair
MAE: mobility assistive equipment
MD: muscular dystrophy
MS: multiple sclerosis
NARIC: National Rehabilitation Information Center
NRRTS: National Registry of Rehabilitation Technology Suppliers
OT: occupational therapy
PAPAW: push rim activated power assist wheelchair
PMD: power mobility device
PT: physical therapy
RA: rheumatoid arthritis
SB: spina bifida
SCI: spinal cord injury
SMS: seating and mobility specialist
VA: Veterans Administration
WHO: World Health Organization